# Scientific Evidence

## Epidemiology and Clinical Consequences

Chlamydia trachomatis is the most common sexually transmitted bacterial pathogen in the United States. There are estimated to be 3 million new infections each year. Chlamydial infection can cause urethritis, cervicitis, pelvic inflammatory disease (PID), and result in ectopic pregnancy, infertility, and chronic pelvic pain in women. In men, chlamydial infection can cause nongonococcal urethritis and acute epididymitis, and result in infertility, chronic prostatitis, reactive arthritis, and urethral strictures. In pregnant women, chlamydial infection is associated with adverse pregnancy outcomes, including preterm delivery and postpartum endometritis; perinatal transmission to infants can cause neonatal conjunctivitis and pneumonia. Chlamydial infection increases the risk of acquiring HIV infection.

Seventy percent to 90% of women and a large percentage of men with chlamydial infection are asymptomatic. The prevalence of asymptomatic infection varies widely depending on the population tested and individual characteristics and risk factors, ranging from 4% to 12% among female family planning clinic patients, 9% among female Army recruits, and 2% to 7% among female college students. Significant declines in prevalence have been noted over the last 10 years in areas where screening programs have been in place.

## Accuracy and Reliability of Screening Test

A number of tests are available to identify chlamydial infection that use endocervical or urethral swab specimens and urine specimens. Until recently, culture has been accepted as the most specific test but it requires specialized handling and laboratory services. Antigen-detection tests (direct fluorescent antibody [DFA] assay and enzyme immunoassay [EIA]) and non-amplified nucleic acid hybridization, as well as newer technologies based on amplified DNA assays (polymerase chain reaction [PCR], ligase chain reaction [LCR], strand displacement assay [SDA], hybrid capture system [HCS] and transcription-mediated amplification [TMA] of RNA) may provide improved sensitivity, lower expense, availability, or timeliness of results over culture. New tests that use urine specimens provide a noninvasive method of screening both men and women. Self-administered vaginal and vulval-introital swabs using PCR and LCR, including submitting samples by mail, are being used in research settings. The sensitivities and specificities of nucleic acid amplification tests are all high, ranging from 82% to 100%. The sensitivity of antigen detection tests (EIA, DFA) is slightly lower (70%-80%) but specificity remains high (96%-100%).

## Effectiveness of Early Detection

The strongest evidence supporting screening is a well-designed randomized trial demonstrating that screening women at risk (prevalence of infection 7%) reduced the incidence of PID from 28 per 1000 woman-years to 13 per 1000 woman-years. The prevalence of chlamydial infection has declined in populations that have been targeted by screening programs (primarily women attending family planning and other publicly funded clinics). In addition, two ecologic analyses in Europe reported reductions in ectopic pregnancy and PID with the advent of community-based screening for chlamydial infection. There is little evidence of the effectiveness of screening asymptomatic women who are not in high-risk groups.

There is fair evidence indicating that screening for chlamydial infection among asymptomatic high-risk pregnant women and subsequent treatment improves pregnancy outcomes. Two nonrandomized trial studies demonstrated improved pregnancy outcomes following treatment of chlamydial infection: less premature rupture of membranes, less low birth weight, higher infant survival, and fewer small-for-gestational age births. There is little evidence regarding the effectiveness of screening and treatment of asymptomatic pregnant women who are not in high-risk groups.

There is good evidence showing that treatment of men can eradicate chlamydial infection. Unfortunately, there are no studies describing the effectiveness of screening or early treatment of men in reducing acute infection and sequelae in men or women.

## Potential Adverse Effects of Screening

No studies were identified that directly examined adverse effects of screening. Potential harms include adverse effects of both false-positive and true-positive diagnoses of an STD on patients and their partners, the inconvenience of pelvic examinations for tests employing cervical specimens, and the potential harms of adverse reactions from antibiotic treatment. There may be added cost for confirmation of positive results and testing of partners.