# Summary of Recommendations

- The U.S. Preventive Services Task Force (USPSTF) strongly recommends that clinicians routinely screen all sexually active women aged 25 years and younger, and other asymptomatic women at increased risk for infection, for chlamydial infection (see Clinical Considerations for discussion of risk factors). (A recommendation). The USPSTF found good evidence that screening women at risk for chlamydial infection reduces the incidence of pelvic inflammatory disease and fair evidence that community-based screening reduces prevalence of chlamydial infection. The USPSTF concludes that the benefits of screening substantially outweigh the potential harms. (Select Potential Adverse Effects of Screening for discussion of potential harms).
- The USPSTF makes no recommendation for or against routinely screening asymptomatic low-risk women in the general population for chlamydial infection. (C recommendation). The USPSTF found at least fair evidence that screening low-risk women could detect some additional cases of Chlamydia trachomatis, but concludes that the potential benefits of screening low-risk women may be small and may not justify the possible harms.
- The USPSTF recommends that clinicians routinely screen all asymptomatic pregnant women aged 25 years and younger and others at increased risk for infection for chlamydial infection (see Clinical Considerations for discussion of risk factors in pregnancy). (B recommendation). The USPSTF found at least fair evidence that screening and treatment of women at risk for chlamydial infection improves pregnancy outcomes and concludes that the benefits of screening outweigh potential harms.
- The USPSTF makes no recommendation for or against routine screening of asymptomatic, low-risk pregnant women aged 26 years and older for chlamydial infection. (C recommendation). The USPSTF found fair evidence that the benefits of screening low-risk pregnant women are small and may not justify the possible harms.
- The USPSTF concludes that the evidence is insufficient to recommend for or against routinely screening asymptomatic men for chlamydial infection. (I recommendation). No direct evidence was found to determine whether screening asymptomatic men for chlamydial infection is effective for reducing the incidence of new infections in women. The benefits and harms of screening men cannot be determined, but the potential magnitude of benefits could be large if the effectiveness of screening men can be demonstrated.