# References

1 Kinsinger LA, Harris, R, Lewis C, Woddell M. Chemoprevention of Breast Cancer: A review of the Evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;37:56-67.
2 Kinsinger LA, Harris, R, Lewis C, Woddell M. Chemoprevention of Breast Cancer Systematic Evidence Review No. 8(Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-97-0011)., Rockville,, MD:. Agency for Healthcare Research and Quality, July 2002. Available on the AHRQ Web site at http://www.ahrq.gov/clinic/serfiles.htm
3 Jemal A, Thomas A, Murray T, Thun M. Cancer statistics, 2002. CA Cancer J Clin. 2002;52:23-47. [pmid: 11814064].
4 Early Breast Cancer Trialists' Collaborative Group. Systemic treatment of early breast cancer by hormonal, cytotoxic, or immune therapy: 133 randomised trials involving 31,000 recurrences and 24,000 deaths among 75,000 women. Lancet. 1992;339:1-15. [pmid: 1345950].
5 Early Breast Cancer Trialists' Collaborative Group. Tamoxifen for early breast cancer: an overview of the randomised trials. Lancet. 1998;351:1451-67. [pmid: 9605801].
6 Powles T, Eeles R, Ashley S, et al. Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352:98-101. [pmid: 9672274].
7 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90:1371-88. [pmid: 9747868].
8 Veronesi U, Maisonneuve P, Costa A, Sacchini V, Maltoni C, Robertson C, Rotmensz N, Boyle P. Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Italian Tamoxifen Prevention Study. Lancet. 1998;352:93-7. [pmid: 9672273].
9 Cummings SR, Eckert S, Krueger KA, et al. The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA. 1999;281:2189-97. [pmid: 10376571].
10 American College of Obstetricians and Gynecologists. Tamoxifen and the prevention of breast cancer in high-risk women ACOG Committee Opinion 224, Washington,, DC. ACOG,1999 325679
11 Chlebowski RT, Collyar DE, Somerfield MR, Pfister DG. American Society of Clinical Oncology Technology Assessment on Breast Cancer Risk Reduction Strategies: Tamoxifen and Raloxifene. J Clin Oncol. 1999;17:1939-54. [pmid: 10561236].
12 Levine M, Moutquin JM, Walton R, Feightner J. Chemoprevention of breast cancer. A joint guideline from the Canadian Task Force on Preventive Health Care and the Canadian Breast Cancer Initiative's Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ. 2001 Jun 12;164:1681-90. [pmid: 11450210]. [pmcid: 81154].
13 Gail MH, Costantino JH, Bryant J, et al. Weighing the risks and benefits of tamoxifen treatment for preventing breast cancer. J Natl Cancer Inst. 1999;91:1829-46. [pmid: 10547390]. [pmcid: 43257].