# Recommendations of Others

The American College of Obstetricians and Gynecologists emphasizes the importance of clinician judgment and recommends that any decision to use tamoxifen be made on an individual basis after consideration of the patient's medical history, risk assessment, and preferences, and with attention to the ability to manage complications of therapy.^10^ The American Society of Clinical Oncology suggests that women with a 5-year projected risk for breast cancer greater than or equal to 1.66 percent may be offered tamoxifen to reduce their risk. They also recommend that raloxifene use should be reserved for treatment of osteoporosis in postmenopausal women.^11^ The Canadian Task Force on Preventive Health Care recommends that clinicians counsel women at high risk for breast cancer (Gail index > 1.66 percent for 5 years) about the potential benefits and harms of breast cancer prevention with tamoxifen.^12^