# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Gaynes B. Screening for suicide risk in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140:822-35. [pmid: 15148072].
3 Gaynes B. Screening for Suicide Risk. Systematic Evidence Review No. 32 (Prepared by the Research Triangle Institute‐University of North Carolina Evidence‐based Practice Center under Contract No. 290‐97‐0011). Rockville, MD: Agency for Healthcare Research and Quality. May 2004. (Available on the AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm).
4 National Center for Injury Prevention and Control. WISQARS (Web‐based Injury Statistics Query and Reporting System). Available at: http://www.cdc.gov/ncipc/. Accessed June 19, 2003.
5 Safer DJ. Adolescent/adult differences in suicidal behavior and outcome. Ann Clin Psychiatr. 1997;9(1):61-6.
6 Minino AM, Arias E, Kochanek KD, Murphy SL, Smith BL. Deaths: final data for 2000. Natl Vital Stat Rep. 2002;50(15):1-119. [pmid: 12382630].
7 Brown GK, Beck AT, Steer RA, Grisham JR. Risk factors for suicide in psychiatric outpatients: a 20‐year prospective study. J Consult Clin Psychol. 2000;68(3):371-7. [pmid: 10883553].
8 National Institute of Mental Health. Suicide facts. Available at: http://www.nimh.nih.gov/research/suifact.cfm. Accessed June 30, 2002.
9 Mann JJ. A current perspective of suicide and attempted suicide. Ann Intern Med. 2002;136(4):302-11. [pmid: 11848728].
10 Kessler RC, Borges G, Walters EE. Prevalence of and risk factors for lifetime suicide attempts in the National Comorbidity Survey. Arch Gen Psychiatry. 1999;56(7):617-26. [pmid: 10401507].
11 Gunnell D, Frankel S. Prevention of suicide: aspirations and evidence. BMJ. 1994;308(6938):1227-33. [pmid: 8080520]. [pmcid: 2540097].
12 Hirschfeld RM, Russell JM. Assessment and treatment of suicidal patients. N Engl J Med. 1997;337(13):910-15. [pmid: 9302306].
13 Borowsky IW, Resnick MD, Ireland M, Blum RW. Suicide attempts among American Indian and Alaska Native youth: risk and protective factors. Arch Pediatr Adolesc Med. 1999;153(6):573-80. [pmid: 10357296].
14 Olfson M, Weissman MM, Leon AC, Sheehan DV, Farber L. Suicidal ideation in primary care. J Gen Intern Med. 1996;11(8):447-53. [pmid: 8872781].
15 Beck AT, Kovacs M, Weissman A. Assessment of suicidal intention: the Scale for Suicide Ideation. J Consult Clin Psychol. 1979;47(2):343-52. [pmid: 469082].
16 Reynolds W. Suicide Ideation Questionnaire. Odessa, Fl: Psychological Assessment Resources. 1987.
17 Rotheram‐Borus MJ, Piacentini J, Cantwell C, Belin TR, Song J. The 18‐month impact of an emergency room intervention for adolescent female suicide attempters. J Consult Clin Psychol. 2000;68(6):1081-93. [pmid: 11142542].
18 McNamee JE, Offord DR. Prevention of suicide. In: Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventive Health Care. Ottawa: Health Canada. 1994; 456‐467. Available at http://www.ctfphc.org/Full_Text/Ch40full.htm. Accessed April 18, 2003.
19 Suicide and suicide attempts in adolescents. Committee on Adolescents. American Academy of Pediatrics Pediatrics 2000 105(4 Pt 1) 871 4 10742340
20 American Academy of Child and Adolescent Psychiatry. Practice parameter for the assessment and treatment of children and adolescents with suicidal behavior J Am Acad Child Adolesc Psychiatry 2001 40(7 Suppl) 24S 51S 11434483
21 American Medical Association. Guidelines for Adolescent Preventive Services (GAPS): Recommendation 20. In: The GAPS Recommendations Monograph; 1997. Available at: http://www.ama‐assn.org/ama/upload/mm/39/gapsmono.pdf (http://www.ama-assn.org/ama/upload/mm/39/gapsmono.pdf). Accessed April 18, 2003.