# Recommendations of Others

The Canadian Task Force on the Periodic Health Examination (now the Canadian Task Force on Preventive Health Care) has found insufficient evidence to recommend for or against routine evaluation of suicide risk and recommends that physicians should remain alert to the possibility of suicide in high‐risk patients, particularly if there is evidence of psychiatric disorder, depression, or substance abuse or if the patient has recently attempted suicide or has a family member who committed suicide.^18^ The American Academy of Pediatrics recommends asking about depression, substance abuse, suicidal thoughts, and other risk factors associated with suicide risk in routine history taking throughout adolescence.^19^ The American Academy of Child and Adolescent Psychiatry recommends that clinicians be aware of patients at high risk for suicide (older male adolescents or adolescents of either sex, regardless of age, who have a current mental disorder or disordered mental state [such as depression, mania or hypomania, or mixed states], especially when complicated by comorbid substance abuse, irritability, agitation, or psychosis).^20^ The American Medical Association Guidelines for Adolescent Preventive Services (GAPS) recommend that all adolescents be asked annually about behaviors or emotions that indicate risk for suicide.^21^