# Discussion

Although the incidence of suicide is low in the general population (0.01%), it was the 11th leading cause of death in the United States in 2000, with an age‐adjusted rate of 10.6 per 100,000 people.^4^ Adolescents and the elderly are particularly at risk for suicide.^5^ ^,^ ^6^ Risk factors for attempted suicide include mood disorders, comorbid substance abuse disorders, and a history of previous suicide attempts.^7^ Additional risk factors for attempted suicide in youth are aggressive or disruptive behavior and history of physical and sexual abuse.^8^ Two‐thirds of suicidal deaths occur on the first attempt, with higher completion rates in men than in women.^9^ ^,^ ^10^ Although men complete suicide more often than women, women attempt suicide more often than men.^10^ Between 3% and 5% of those who have had an episode of DSH die by suicide within 5 to 10 years.^11^ More than 90% of those who complete suicide have a psychiatric illness at the time of death, usually depression, alcohol abuse, or both.^12^ Almost 75% of suicides are completed by white males who have a 2‐fold higher risk for suicide than do black males (19.1/100,000 vs 10.4/100,000).^4^ Native Americans are also at high risk for suicide.^13^

The USPSTF reviewed the evidence for the effectiveness of identification and treatment for suicide risk in the primary care setting. Because no direct evidence was found regarding the impact of screening on suicide attempts or completions, the USPSTF examined the accuracy of screening tests and the efficacy of treatment on intermediate outcomes, such as reduced suicidal ideation, reduced severity of depression, reduced hopelessness, and improved level of functioning. Their review did not include studies of populations with chronic psychiatric illnesses because people in this group would already have been identified as being at risk for suicide.

Little is known about screening instruments to assess suicide risk in primary care populations. Only 1 study of good quality evaluated a screening instrument, the 62‐item SDDS‐PC, for the identification of patients with psychiatric illnesses in the primary care setting.^14^ One of its items for assessing suicide risk, "feeling suicidal," was predictive of plans to attempt suicide with reasonable test characteristics (83% sensitivity, 98% specificity, and a 30% positive predictive value). However, the study has not been replicated, nor has the specific item been tested independent of the longer instrument. Two studies of fair to poor quality evaluated the 21‐item SSI and the SSI‐W in adult psychiatric outpatients.^7^ ^,^ ^15^ Patients who scored in the higher‐risk category in the SSI and SSI‐W were more likely to commit suicide than those who scored in the lower‐risk category (approximately 7 and 14 times more likely, respectively). The shortened 4‐item Suicidal Ideation Questionnaire (SIQ‐JR), developed to identify adolescents at risk for suicide in emergency room settings, has 98% sensitivity, 37% specificity, and a 55% positive predictive value.^16^ None of these 3 screening instruments has been evaluated in the primary care setting. No studies were found that assessed instruments for screening patients at high risk for suicide in primary care populations.

In the USPSTF review, 33 randomized controlled trials addressed the effect of treatment of those patients with a history of suicide attempts on health outcomes and mortality.^3^ Thirty‐one of these trials required recent DSH; the other 2 trials enrolled patients with borderline personality disorder (at least 75% of whom had a history of DSH in these 2 studies). With respect to the outcomes on suicide attempts and completion, no statistically significant effects of interventions were found for which more than 1 study of the intervention had been performed. However, some trends suggested incremental benefits from some interventions (in particular, problem‐solving therapy for patients aged 15 or older). Of the interventions for which only 1 study was conducted, the most promising are dialectical behavior therapy (DBT) for adults with borderline personality disorder, interpersonal psychotherapy (IPT) for adults with DSH, and group therapy for younger adolescents with DSH. No studies were found that evaluated treatment for suicide risk in the geriatric population. The studies comprising the evidence base have 3 primary limitations: first, studies tend to be underpowered; second, standard care is poorly described and likely varies across multiple studies; and third, there is a lack of stratification based on age and age ranges are inconsistent across studies. This limits the ability of the USPSTF to draw meaningful conclusions about the effects of these interventions on future suicide attempts or suicides.

Several studies of fair quality evaluated the effect of treatment on the intermediate outcomes of suicidal ideation, depressive severity, hopelessness, and level of functioning in high‐risk patients. No studies recruited patients from primary care settings. Improvements were described in patients with a history of DSH who participated in problem‐solving therapy, and in women with borderline personality disorder who were treated using DBT, antidepressant therapy, cognitive behavioral counseling, and interpersonal psychotherapy. Among children aged 18 and younger, who have a history of attempted suicide, brief emergency crisis intervention involving mother and daughter decreased depressive symptoms at the 18‐month followup.^17^

No studies have directly addressed the harms of either screening or treatment of primary care patients at risk for suicide. Two studies found contradictory results regarding the harms of treatment interventions in a population of patients with a history of DSH compared with patients with no history of DSH.^3^