# Clinical Considerations

- The strongest risk factors for attempted suicide include mood disorders or other mental disorders, comorbid substance abuse disorders, history of deliberate self‐harm (DSH), and a history of suicide attempts. DSH refers to intentionally initiated acts of self‐harm with a non‐fatal outcome (including self‐poisoning and self‐injury). Suicide risk is assessed along a continuum ranging from suicidal ideation alone (relatively less severe) to suicidal ideation with a plan (more severe). Suicidal ideation with a specific plan of action is associated with a significant risk for attempted suicide.
- Screening instruments are commonly used in specialty clinics and mental health settings. The test characteristics of most commonly‐used screening instruments (Scale for Suicide Ideation [SSI], Scale for Suicide Ideation—Worst [SSI‐W], and the Suicidal Ideation Questionnaire [SIQ)]) have not been validated to assess suicide risk in primary care settings. There has been limited testing of the Symptom‐Driven Diagnostic System for Primary Care (SDDS‐PC) screening instrument in a primary care setting.