# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Hartman KE, Hall SA, Nanda K, Boggess JF, Zolnoun D. Screening for Cervical Cancer. Systematic Evidence Review. No. 25. (Prepared by the Research Triangle Institute‐University of North Carolina Evidence‐based Practice Center under contract No. 290‐97‐0011). Rockville, MD: Agency for Healthcare Research and Quality. January 2002. Available on the AHRQ Web site: at: http://www.ahrq.gov/clinic/serfiles.htm.
3 Martin‐Hirsch P, Lilford R, Jarvis G, Kitchener HC. Efficacy of cervical‐smear collection devices: a systematic review and meta‐analysis [published erratum appears in Lancet 2000 Jan 29;355(9201):414]. Lancet. 1999;354(9192):1763-1770. [pmid: 10577637].
4 Smith RA, Cokkinides V, von Eschenbach AC, et al. American Cancer Society Guideline for the Early Detection of Cervical Neoplasia and Cancer. CA Cancer J Clin. 2002;52(1):8-22. [pmid: 11814067].
5 Hildesheim A, Hadjimichael O, Schwartz PE, et al. Risk factors for rapid‐onset cervical cancer. Am J Obstet Gynecol. 1999;180(3 Pt 1):571-577. [pmid: 10076130].
6 Janerich DT, Hadjimichael O, Schwartz PE, et al. The screening histories of women with invasive cervical cancer, Connecticut. Am J Public Health. 1995;85(6):791-794. [pmid: 7762711]. [pmcid: 1615485].
7 American College of Obstetricians and Gynecologists. Guidelines for Women's Health Care. 2nd ed. Washington, DC: ACOG;2002: 121‐134, 140‐141.
8 Mitchell HS, Giles GG. Cancer diagnosis after a report of negative cervical cytology. Med J Aust. 1996;164(5):270-273. [pmid: 8628160].
9 Sigurdsson K. Trends in cervical intra‐epithelial neoplasia in Iceland through 1995: evaluation of targeted age groups and screening intervals. Acta Obstet Gynecol Scand. 1999;78(6):486-492. [pmid: 10376857].
10 American Cancer Society. Cancer facts and figures, 2002. Atlanta: American Cancer Society, 2002. Accessed at http://www.cancer.org/docroot/STT/stt_0.asp on November 12, 2002.
11 U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. 2nd ed. Washington, DC: U.S. Government Printing Office, November 2000.
12 de Vet HC, Sturmans F, Knipschild PG. The role of cigarette smoking in the etiology of cervical dysplasia. Epidemiology. 1994;5(6):631-633. [pmid: 7841245].
13 Winkelstein W. Smoking and cervical cancer — current status: a review. Am J Epidemiol. 1990;131(6):945-957. [pmid: 2188500].
14 Lyon JL, Gardner JW, West DW, Stanish WM, Hebertson RM. Smoking and carcinoma in situ of the uterine cervix. Am J Public Health. 1983;73(5):558-562. [pmid: 6837821]. [pmcid: 1650827].
15 International Agency for Research on Cancer (IARC). Summaries and Evaluations: Human Papillomaviruses. Lyons: IARC; 1995;64. Available at http://www.inchem.org/documents/iarc/iarc/iarc782.htm. Accessed November 13, 2002.
16 Bosch FX, Manos MM, Munoz N, et al. Prevalence of human papillomavirus in cervical cancer: a worldwide perspective. International biological study on cervical cancer (IBSCC) Study Group. J Natl Cancer Inst. 1995;87(11):796-802. [pmid: 7791229].
17 Jacobs MV, Snijders PJ, van den Brule AJ, Helmerhorst TJ, Meijer CJ, Walboomers JM. A general primer GP5+/GP6(+)‐mediated PCR‐enzyme immunoassay method for rapid detection of 14 high‐risk and 6 low‐risk human papillomavirus genotypes in cervical scrapings. J Clin Microbiol. 1997;35(3):791-795. [pmcid: 229677]. [pmid: 9041439].
18 McCrory DC, Mather DB, Bastian L. Evaluation of Cervical Cytology: Evidence Report/Technology Assessment No. 5. (Prepared by Duke University under Contract No. 290‐97‐0014.) AHCPR Publication No. 99‐E010. Rockville, MD: Agency for Health Care Policy and Research. February 1999. Available at http://www.ahrq.gov/clinic/epcindex.htm. Accessed November 25, 2002.
19 Cuzick J, Beverley E, Ho L, et al. HPV testing in primary screening of older women. Br J Cancer. 1999;81(3):554-558. [pmid: 10507785].
20 Kulasingam SL, Hughes JP, Kiviat NB, et al. Evaluation of human papillomavirus testing in primary screening for cervical abnormalities: comparison of sensitivity, specificity, and frequency of referral. JAMA. 2002;288(14):1749-57. [pmid: 12365959].
21 Sawaya GF, Grady D, Kerlikowske K, et al. The positive predictive value of cervical smears in previously screened postmenopausal women: the Heart and Estrogen/progestin Replacement Study (HERS). Ann Intern Med. 2000;133(12):942-50. [pmid: 11119395].
22 Fox J, Remington P, Layde P, Klein G. The effect of hysterectomy on the risk of an abnormal screening Papanicolaou test result. Am J Obstet Gynecol. 1999;180(5):1104-1109. [pmid: 10329862].
23 Pearce K, Haefner H, Sarwar S, Nolan T. Cytopathological findings on vaginal Papanicolaou smears after hysterectomy for benign gynelogical disease. N Engl J Med 1996(21);335:1559‐1562.
24 Ries LA, Kosary CL, Hankey BF, et al., eds.: SEER Cancer Statistics Review 1973‐1995. Bethesda, Md: National Cancer Institute, 1998.
25 International Agency for Research on Cancer (IARC) Working Group on the Evaluation of Cervical Cancer Screening Programmes. Screening for squamous cervical cancer: duration of low risk after negative results of cervical cytology and its implication for screening policies Br Med J 1986 293 6548 659 664 3092971 1341512
26 Sasieni PD, Cuzick J, Lynch‐Farmery E. Estimating the efficacy of screening by auditing smear histories of women with and without cervical cancer. The National Co‐ordinating Network for Cervical Screening Working Group. Br J Cancer. 1996;73(8):1001-1005. [pmid: 8611418].
27 Sawaya GF, Kerlikowske K, Lee NC, Gildengorin G, Washington AE. Frequency of cervical smear abnormalities within 3 years of normal cytology. Obstet Gynecol. 2000;96(2):219-23. [pmid: 10908766].
28 American Academy of Family Physicians. Summary of Policy Recommendations for Periodic Health Examinations, December, 2001. Available at www.aafp.org/exam.xml . Accessed January 23, 2002.
29 Hawkes AP, Kronenberger CB, MacKenzie TD et al. American College of Preventive Medicine. Practice Policy Statement: Cervical Cancer Screening. Am J Prev Med 1996;12(5):342‐4. Available at http://www.acpm.org/cervical.htm. Accessed January 23, 2002.
30 American Medical Association. Cancer screening guidelines. Available at www.ama‐assn.org. Accessed September 6, 2001.
31 Morrison BJ. Screening for Cervical Cancer. In: Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventive Health Care. Ottawa: Health Canada, 1994; 870‐881. (Reviewed in 1999). Available at www.ctfphc.org/Full_Text_printable/Ch73full.htm. Accessed January 23, 2002.
32 American Academy of Pediatrics, Committee on Psychosocial Aspects of Child and Family Health. Guidelines for Health Supervision III. Elk Grove Village, IL: American Academy of Pediatrics; 1997.