# Appendix B. USPSTF Strength of Overall Evidence

The USPSTF grades the quality of the overall evidence for a service on a 3‐point scale (good, fair, poor):

Good: Evidence includes consistent results from well‐designed, well‐conducted studies in representative populations that directly assess effects on health outcomes.

Fair: Evidence is sufficient to determine effects on health outcomes, but the strength of the evidence is limited by the number, quality, or consistency of the individual studies, generalizability to routine practice, or indirect nature of the evidence on health outcomes.

Poor: Evidence is insufficient to assess the effects on health outcomes because of limited number or power of studies, important flaws in their design or conduct, gaps in the chain of evidence, or lack of information on important health outcomes.