# Scientific Evidence

## Epidemiology and Clinical Consequences

Breast cancer is the most common non-skin cancer in women. An estimated 203,500 new cases of invasive breast cancer will be diagnosed in 2002, and 39,600 women will die from the disease.^3^ Although the USPSTF concluded that early detection of breast cancer through mammography has reduced deaths from breast cancer, the effectiveness of mammography is limited. Another approach to reducing breast cancer deaths is chemoprevention for primary prevention of cancer.

## Potential Benefits of Chemoprevention

The use of agents to prevent the development of breast cancer was suggested by trials of breast cancer treatment with tamoxifen, a compound with both estrogen-like and anti-estrogen properties (a selective estrogen receptor modulator).^4^ A meta-analysis of 55 studies evaluating tamoxifen for the treatment of women with breast cancer found that the drug was associated with an approximately 50 percent reduction in the risk for developing new cancers in the opposite breast among women who took the drug for 5 years.^5^

The USPSTF found and evaluated 4 randomized controlled trials (RCTs) of breast cancer chemoprevention in women who had never had breast cancer.^4^ Three of these trials used tamoxifen as the chemopreventive agent^6-8^; one trial used raloxifene, another selective estrogen receptor modulator.^9^

Of the 3 RCTs of tamoxifen, the largest (the Breast Cancer Prevention Trial-BCPT), with 13,388 women enrolled, found a risk reduction of invasive cancer of 49 percent among women at high risk for breast cancer (estimated 5-year risk of 1.66 percent or greater).^7^ Over the course of the BCPT, a total of 264 women were diagnosed with invasive breast cancer: 175 in the placebo group and 89 in the tamoxifen group (RR, 0.51; 95 percent CI, 0.39-0.66). The absolute risk reduction was 21.4 cases per 1,000 women over 5 years.

The two other tamoxifen RCTs did not show a similar benefit. The relative risk reduction for breast cancer was 0.94 (95 percent CI, 0.59 -1.43) for the Royal Marsden Hospital study^6^ and 0.87 (95 percent CI, 0.62-2.14) for the Italian Tamoxifen Prevention Study.^8^ Although the reasons for these discrepant results are not definitively established, possible explanations include differences in the duration of therapy and differences between women enrolled in each study.^1^ The average duration of therapy was shorter in the European trials and, compared with the women enrolled in BCPT, the women in these trials were younger, had more estrogen-receptor-negative cancers, and were more likely to be taking hormone replacement therapy or to have had an oopherectomy.^1^

The study evaluating raloxifene in postmenopausal women with osteoporosis found a 76 percent risk reduction (RR, 0.24; 95 percent CI, 0.13-0.44) in the development of invasive breast cancer.^9^ After a median followup of 40 months, the absolute risk reduction among women taking raloxifene was 7.9 cases per 1,000 women (number needed to treat, 126).^9^ When effective, both raloxifene and tamoxifen were effective only against estrogen receptor-positive tumors.^1^

## Potential Harms of Chemoprevention

Both tamoxifen and raloxifene increase the risk for thromboembolic events and hot flashes; tamoxifen increases the risk for endometrial cancer.^1^ The number of total thromboembolic events in all four trials was small, and differences in specific complication rates between the treatment and placebo arms were statistically significant only for pulmonary embolism.^1^ Among women aged 50 and older, for whom the potential harms of tamoxifen and raloxifene are more common than they are for younger women, the BCPT reported that after a median of 55 months of use, tamoxifen:

- Increased the rate of stroke from 1.3 cases/1,000 women in the placebo group to 2.2 cases/1,000 women in the study group (RR, 1.75; 95 percent CI, 0.98-3.20).
- Increased the rate of pulmonary embolism from 0.3 cases/1,000 women in the placebo group to 1.0 cases/1,000 women in the study group (RR, 3.19 percent; 95 percent CI, 1.12-11.15).
- Increased the rate of deep vein thrombosis from 0.9 cases/1,000 women in the placebo group to 1.5 cases/1,000 women in the study group (RR, 1.71; 95 percent CI, 0.85-3.58).^7^

Fewer thromboembolic events occurred among women younger than 50, and the trial found no significant difference in incidence between the tamoxifen and placebo groups in this age group.^7^ The relative risk increase in venous thromboembolism from tamoxifen or raloxifene appears similar to the risk for venous thromboembolism from oral contraceptives or hormone replacement therapy.^1^

Among women aged 50 and older in the BCPT, participants who received tamoxifen, compared with those who took placebo, had a 4.0 times greater risk (95 percent CI, 1.70-10.90) of developing Stage 1 endometrial cancer (0.8 cancers/1,000 women taking placebo vs 3.1 cancers/1,000 women taking tamoxifen for a median of 55 months).^7^ Among women younger than 50, the BCPT found no significant difference in endometrial cancer rates between the two groups. No deaths attributed to endometrial cancer occurred in the trial.^7^ Raloxifene has not been associated with an increase in endometrial cancer.^9^

The BCPT reported that women in the tamoxifen group were at increased risk for developing cataracts and having cataract surgery compared with placebo (RR, 1.14 [95 percent CI, 1.01-1.29] and 1.57 [95 percent CI, 1.16-2.14], respectively).^7^

Quality-of-life issues have also been of concern and were addressed in the BCPT. Women in the BCPT reported increased rates of bothersome hot flashes (45.7 percent in the tamoxifen group vs 28.7 percent in the placebo group) and bothersome vaginal discharge (12.4 percent in the tamoxifen group vs 4.5 percent in the placebo group).^7^ Women given raloxifene also noted higher rates of hot flashes than women given placebo (10.7 percent in the ralixifene group vs 6.4 percent in the placebo group).^9^

Although long-term adherence for highly motivated women was about 80 percent in the BCPT trial and about 90 percent in the raloxifene trial, adherence rates in the general population are unknown.^2^