# Scientific Evidence

## Epidemiology and Clinical Consequences

Approximately 13,000 new cases of cervical cancer and 4,100 cervical cancer‐related deaths were projected to occur in 2002 in the United States. Rates in the United States have decreased from 14.2 new cases per 100,000 women in 1973 to 7.8 cases per 100,000 women in 1994. Despite falling incidence, cervical cancer remains the tenth leading cause of cancer death.^10^ The Healthy People 2010 target for cervical cancer is a reduction in mortality to 2.0 deaths per 100,000 women. Since 1998, the rate remains near 3.0 deaths per 100,000 women.^11^

Squamous cell carcinoma of the cervix and its cytologic precursors occur among women who are sexually active. Risk factors relating to sexual behavior associated with an increased risk of cervical cancer include early onset of intercourse and a greater number of lifetime sexual partners. Cigarette smoking is the only nonsexual behavior consistently and strongly correlated with cervical dysplasia and cancer, independently increasing risk two‐ to four‐fold. ^12^ 14 (http://www.ahrq.gov/clinic/3rduspstf/cervcan/cervcanrr.htm#reference14#reference14)

Infection with high‐risk strains of human papilloma virus (HPV), generally acquired sexually, is the most important risk factor for cervical cancer. Using modern HPV detection methods, 95‐100 percent of squamous cell cervical cancer and 75‐95 percent of high‐grade CIN lesions have detectable HPV DNA.^15^ 17 (http://www.ahrq.gov/clinic/3rduspstf/cervcan/cervcanrr.htm#reference17#reference17) HPV is a necessary but insufficient precursor of squamous cell carcinoma of the cervix. Host factors such as age, nutritional status, immune function, smoking, and possibly silent genetic polymorphisms modulate incorporation of viral DNA into host cervical cells. In the United States, peak incidence and prevalence of HPV infection occur among women younger than 25 but most infections in younger women are transient. Infections with HPV in older women are much less prevalent but carry a higher risk of progressing to cervical neoplasia. Although the prevalence of HPV infection is higher among immunocompromised hosts such as HIV‐infected women, the speed of progression to cervical cancer is not increased. Natural history studies confirm that, in the vast majority of cases, the course of infection and cervical abnormalities that progress do so in an orderly fashion from less severe to more severe lesions.

## Accuracy and Reliability of Screening Tests

Cervical cancer screening tests potentially appropriate for primary care settings include cervical cytology, conventional and new technologies, and tests for HPV infection.

### Screening Using Cytologic Methods

The USPSTF did not re‐examine test characteristics of conventional cervical cytology smears. A previous review estimated that the sensitivity of a single Pap test was 60‐80 percent for high‐grade lesions, and even lower for low‐grade lesions.^18^ The USPSTF review focused on new evidence about thin layer cytology (ThinPrep® , AutoCyte PREP® ), computerized rescreening (PapNet® ), and algorithm‐based screening (AutoPap® ), all recent technical extensions of conventional cytology methods. The USPSTF found few studies testing the new technologies against an adequate reference standard (colposcopy or histology) and few that included validation of normal screening test results.^2^ ^,^ 18 (http://www.ahrq.gov/clinic/3rduspstf/cervcan/cervcanrr.htm#reference18#reference18) As a result, sensitivity, specificity, and predictive values of the new technologies cannot be directly assessed or compared with the test characteristics of conventional cytology in the same population. Furthermore, no prospective studies have compared the new technologies to conventional Pap screening using the most important health outcomes (e.g., invasive cervical cancer) or costs and cost‐effectiveness. The only model identified finds that new technologies are more costly than conventional cytology and that new technologies will fall within the traditional range considered to be cost‐effective ($50,000 per life‐year) only if used in screening intervals of 3 years or longer.^18^

In the absence of studies with cervical cancer outcomes, the USPSTF concluded that the available data on the accuracy of new technologies were insufficient to determine whether they are more effective than conventional cervical cytology for preventing invasive cervical cancer.

The literature provides fairly reliable estimates of the number of women who need to be screened to detect serious lesions. Among previously screened women with a history of normal Pap tests, fewer than 1 woman in 1,000 screened (in some scenarios as few as 1 woman in 10,000) will have a high‐grade cytologic abnormality. As an example, if the sensitivity of cytology is 60 percent and the specificity is 98 percent for detection of high‐grade abnormalities, then 34 women will be evaluated for high‐grade squamous intraepithelial lesions for each true high‐grade cervical lesion identified; moreover, 2 high‐grade lesions will have been missed by cytology for every 3 cases identified. The ratio of true positives to false positives is much higher if low‐grade cytologic changes are considered, but many of these will regress without treatment.^18^

### Screening Using Tests for HPV

Six studies prior to 2002 examined the role of HPV as a primary screening test, five of which used a study population at high risk for cervical dysplasia. Only 1 study of 2,988 women having routine cervical cancer screening at 40 general practitioner practices in the U.K. approximates screening use in routine primary care practice in the United States.^19^ In conditions of low prevalence of high‐grade squamous intraepithelial lesions (HSIL) typical of primary care practice, the USPSTF estimated sensitivity of testing for HPV using Hybrid Capture II for HSIL at 82 percent; specificity, 78 percent; positive predictive value, 18 percent; and negative predictive value, 99 percent. The estimated sensitivity of testing for HPV using Hybrid Capture II for LSIL was 66 percent; specificity, 91 percent; positive predictive value, 26 percent; and negative predictive value, 98 percent. Similar results were reported in a recent study in Planned Parenthood clinics: both Hybrid Capture II and PCR testing were more sensitive than liquid‐based cytology (88‐91 percent vs 61 percent) but were less specific (73‐79 percent vs 82 percent).^20^

The benefits of HPV testing as an alternative or adjunct to primary Pap screening have not yet been tested in prospective studies. Adding HPV testing to conventional screening is unlikely to be worthwhile, but HPV testing may have a role in primary screening if it can reliably distinguish between women who would benefit from more intensive Pap testing (more frequent, different technologies, or extended over longer periods) and women for whom screening can be less intensive or even discontinued. There are at least eight studies evaluating HPV testing in large populations underway or recently completed but not yet in the published literature. At the same time, there are few data on the potential harms of HPV testing, which may include anxiety or stigmatization among infected women and affects on relationships with sexual partners.

### Special Considerations in Older Women and in Women Who Have Had a Hysterectomy

Multiple studies published since 1995 provide sufficiently detailed information about results of screening by age to examine the evidence about screening among older women.^2^ The incidence and prevalence of cervical intraepithelial neoplasia peak in the mid‐reproductive years and begin to decline in approximately the fourth decade of life, a general pattern also apparent among previously unscreened women. Cervical cancer in older women is not more aggressive or rapidly progressive than in younger women. Finally, the rates of high‐grade squamous intraepithelial lesions diagnosed by cytology are low among older women who have been screened.

These and other data suggest that the risks of high‐grade cervical lesions and cancer fall with age; that a history of prior normal Pap tests further reduces risk; and that if screening recommendations are not modified with age, older women are disproportionately likely to be evaluated for false‐positive findings. In 1 study of more than 2,561 postmenopausal women (average age 67 years) who had normal baseline smears and were generally at low risk for cervical cancer, annual screening done over 4 years produced 110 abnormal results requiring diagnostic evaluations, which generated 231 additional interventions (ranging from repeat Pap smears to colposcopy and biopsies); one case of "mild to moderate dysplasia" was diagnosed.^21^ The difficult trade‐off between over‐screening and missing rare but potentially preventable cases of cervical cancer is a challenge for policy.

Two large series documenting the low risk of cytologic abnormality after hysterectomy have been published since the last USPSTF made its recommendations. A cross‐sectional study of more than 5,000 Pap tests among women older than age 50 documented that identification of dysplasia and cancer was rare in this age group after hysterectomy (0.18/1,000 women screened).^22^ Women after hysterectomy were one tenth as likely as those with a cervix to have any Pap test diagnosis of abnormality. In a second study of nearly 10,000 Pap tests performed over 2 years in 6,265 women who had hysterectomies for benign disease, screening yielded 104 abnormal Pap tests but only 4 high‐grade lesions: 3 cases of vaginal intraepithelial neoplasia and 1 case of squamous cell carcinoma of the vagina (rate of 0.42 high‐grade lesions per 1,000 Pap tests)^23^. Whether detection of these vaginal lesions improved clinical outcomes is unknown.

## Effectiveness of Early Detection

Detection of cervical cancer in its earliest stages is lifesaving, as survival of cancer of the cervix uteri depends heavily on stage at diagnosis. Although 92 percent of women will survive 5 years when the cancer is localized, only 13 percent will survive distant disease.^24^ Introduction of screening programs to populations naïve to screening reduces cervical cancer rates by 60‐90 percent within 3 years of implementation.^25^ ^,^ 26 (http://www.ahrq.gov/clinic/3rduspstf/cervcan/cervcanrr.htm#reference26#reference26) This reduction of mortality and morbidity with introduction of the Pap test is consistent and dramatic across populations. Although no prospective trial of Pap screening has ever been conducted, correlational studies of cervical cancer trends in countries in North America and Europe demonstrate dramatic reductions in incidence of invasive cervical cancer and a 20‐60 percent reduction in cervical cancer mortality.

No prospective studies have directly compared the outcomes of screening at different intervals in a given population. Data from 8 cervical cancer screening programs involving 1.8 million women compared the effects of different intervals among the programs: screening at intervals of 5, 3, 2 years or 1 year was estimated to reduce incidence of invasive disease by 84 percent, 91 percent, 93 percent, and 94 percent, respectively, among women aged 35‐64, assuming perfect compliance. Data from a large screening program in the United States indicate that a longer interval (3 years vs 1 or 2 years) between Pap tests is not associated with a higher risk for developing high‐grade lesions.^27^

## Potential Harms of Screening and Treatment

The USPSTF did not identify studies that specifically addressed harms of new technologies for cervical cancer screening. Better data on the performance characteristics (sensitivity, specificity, and predictive values) of the new screening technologies are needed to determine the risk for harm to an individual patient. Although the data are limited, on average these tools improve sensitivity and reduce specificity. This finding suggests that increased detection of low‐grade lesions and false positives are the primary potential sources of harm; i.e., harm may take the form of increased evaluations, including repeated Pap tests and biopsies; possible unnecessary treatment for low‐grade lesions; and psychological distress for the women diagnosed with low grade lesions that may not have been clinically important. These harms are poorly documented for conventional Pap testing and have not yet been assessed for new technologies.

With regard to HPV testing, the USPSTF did not identify any studies that quantified harms. Potential harms commented on in the literature include stigma, partner discord, adverse effects of labeling some women as being at high risk for cervical cancer, and the potential undermining of routine cytologic screening known to be effective.