# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd edition. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Nelson H, Humphrey L, LeBlanc E, et al. Postmenopausal hormone replacement therapy for the primary prevention of chronic conditions: a summary of the evidence for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality. AHRQ Pub. No. 03‐513A. On the AHRQ Web site at: www.ahrq.gov/clinic/3rduspstf/hrt/hrtsum1.htm
3 Writing Group for the Women's Health Initiative Investigators. Risks and benefits of estrogen plus progestin in healthy postmenopausal women JAMA 2002 288 321 33 12117397
4 Grady D, Rubin S, Petitti D, et al. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992;117:1016-37. [pmid: 1443971].
5 Cancer Facts & Figures 2002: Special section: Colorectal Cancer and Early Detection. Atlanta, GA: American Cancer Society. Available at: www.cancer.org. Accessed June 5, 2002.
6 Torgerson D, Bell‐Syer S. Hormone replacement therapy and prevention of nonvertebral fractures: a meta‐analysis of randomized trials. JAMA. 2001;285(22):2891-7. [pmid: 11401611].
7 Hulley S, Furberg C, Barrett‐Conner E, et al. Non‐cardiovascular disease outcomes during 6.8 years of hormone therapy. JAMA. 2002;288:58-66. [pmid: 12090863].
8 Grodstein F, Newcomb P, Stampfer M. Postmenopausal hormone therapy and the risk of colorectal cancer: a review and meta‐analysis. Am J Med. 1999;106(5):574-82. [pmid: 10335731].
9 LeBlanc E, Chan B, Nelson H. Hormone Replacement Therapy and Cognition. Systematic Evidence Review No. 13 (Prepared by the Oregon Health & Science Evidence‐based Practice Center under Contract No. 290‐97‐0018). Rockville, MD: Agency for Healthcare Research and Quality. August 2002. Available on the AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm.
10 Steinberg K, Smith S, Thacker S, Stroup D. Breast cancer risk and duration of estrogen use: the role of study design in meta‐analysis. Epidemiology. 1994;5:415-21. [pmid: 7918811].
11 Humphrey LL. Hormone Replacement Therapy and Breast Cancer. Systematic Evidence Review No. 14 (Prepared by the Oregon Health & Science Evidence‐based Practice Center under Contract No. 290‐97‐0018). Rockville, MD: Agency for Healthcare Research and Quality. August 2002. Available on the AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm.
12 Colditz G, Hankinson S, Hunter D, et al. The use of estrogens and progestins and the risk of breast cancer in postmenopausal women. N Engl J Med. 1995;332(24):1589-93. [pmid: 7753136].
13 Sellers TA, Mink PJ, Cerhan JR, et al. The role of hormone replacement therapy in the risk for breast cancer and total mortality in women with a family history of breast cancer. Ann Intern Med. 1997;127(11):973-80. [pmid: 9412302].
14 Humphrey LL, Takano L, Chan B. Hormone Replacement Therapy and Cardiovascular Disease. Systematic Evidence Review No.10 (Prepared by the Oregon Health &Science Evidence‐based Practice Center under Contract No. 290‐97‐0018). Rockville, MD: Agency for Healthcare Research and Quality. August 2002. Available on the AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm.
15 Humphrey LL, Chan BK, Sox HC. Postmenopausal hormone replacement therapy and the primary prevention of cardiovascular disease. Ann Intern Med. 2002;137:273-84. [pmid: 12186518].
16 Simon J, Hsia J, Cauley J, et al. Postmenopausal hormone therapy and risk of stroke: The Heart and Estrogen‐progestin Replacement Study (HERS). Circulation. 2001;103(5):638-42. [pmid: 11156873].
17 Viscoli CM, Brass LM, Kernan WN, Sarrel PM, Suissa S, Horwitz RI. A clinical trial of estrogen‐replacement therapy after ischemic stroke. N Engl J Med. 2001;345(17):1243-1249. [pmid: 11680444].
18 Miller J, Chan B, Nelson H. Hormone Replacement Therapy and Risk of Venous Thromboembolism. Systematic Evidence Review No.11 (Prepared by the Oregon Health &Science Evidence‐based Practice Center under contract No. 290‐97‐0018). Rockville, MD: Agency for Healthcare Research and Quality. August 2002. Available on the AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm.
19 Miller J, Chan BK, Nelson HD. Postmenopausal estrogen replacement and risk for venous thromboembolism: a systematic review and meta‐analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136:680-90. [pmid: 11992304].
20 Grady D, Gebretsadik T, Ernster V, Petitti D. Hormone replacement therapy and endometrial cancer risk: a meta‐analysis. Obstet Gynecol. 1995;85:304-313. [pmid: 7824251].
Lacey JJ, Mink p, Lubin J, et al. Menopausal hormone replacement therapy and risk of ovarian cancer. JAMA. 2002;288(3):334-341. [pmid: 12117398].
22 Rodriguez C, Patel A, Calle E, Jacob E, Thun M. Estrogen replacement therapy and ovarian cancer mortality in a large prospective study of US women. JAMA. 2001;285(11):1460-1465. [pmid: 11255422].
23. Persson I, Yuen J, Bergkvist L, Schairer C. Cancer incidence and mortality in women receiving estrogen and estrogen‐progestin replacement therapy—long‐term followup of a Swedish cohort. Int J Cancer. 1996;67(3):327-332. [pmid: 8707404].
24 Grodstein F, Colditz G, Stampfer M. Postmenopausal hormone use and cholecystectomy in a large prospective study. Obstet Gynecol. 1994;83(1):5-11. [pmid: 8272307].
25 Simon J, Hunninghake D, Agarwal S, et al. Effect of estrogen plus progestin on risk for biliary tract surgery in postmenopausal women with coronary artery disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med. 2001;135:493-501. [pmid: 11578152].
26 American College of Obstetricians and Gynecologists. Response to Women's Health Initiative Study Results by the American College of Obstetricians and Gynecologists. August 9, 2002.
27 The North American Menopause Society. Report from the NAMS Advisory Panel on Postmenopausal Hormone Therapy. Available at: http://www.menopause.org/news.html ‐ advisory (http://www.menopause.org/news.html#advisory). Accessed October 8, 2002.
28 American Heart Association. Q & A About Hormone Replacement Therapy. Available at: http://216.185.112.5/presenter.jhtml?identifier=3004068. Accessed October 7, 2002.
29 Nawaz H, Katz DL. American College of Preventive Medicine Practice Policy Statement: perimenopausal and postmenopausal hormone replacement therapy. Am J Prev Med. 1999;17:250-254. [pmid: 10987643].
30 The American Association of Clinical Endocrinologists. Medical guidelines for clinical practice for management of menopause Endocr Pract 1999 5 355 366
31 Sadovsky R. Recent analysis of hormone replacement therapy. Available at: http://www.aafp.org/afp/20000101/tips/17.html. Accessed June 5, 2002.
32 Canadian Task Force on the Periodic Health Examination. Ottawa (Canada): Health Canada. Updates available at: http://www.ctfphc.org/index.html.