# Clinical Considerations

- Clinicians should consider both the risk for breast cancer and the risk for adverse effects when identifying women who may be candidates for chemoprevention. Risk for breast cancer. Older age; a family history of breast cancer in a mother, sister, or daughter; and a history of atypical hyperplasia on a breast biopsy are the strongest risk factors for breast cancer. Table 1 indicates how the estimated benefits of tamoxifen vary depending on age and family history. Other factors that contribute to risk include race, early age at menarche, pregnancy history (nulliparity or older age at first birth), and number of breast biopsies. The risk for developing breast cancer within the next 5 years can be estimated using risk factor information by completing the National Cancer Institute Breast Cancer Risk Tool (the "Gail model," available at http://cancer.gov/bcrisktool/ or 800-4-CANCER). Clinicians can use this information to help individual patients considering tamoxifen therapy estimate the potential benefit. However, the validity, feasibility, and impact of using the Gail model to identify appropriate candidates for chemoprevention has not been tested in a primary care setting. The Gail model does not incorporate estradiol levels or estrogen use, factors that some studies suggest may influence the effectiveness of tamoxifen. Risk for adverse effects. Women are at lower risk for adverse effects from chemoprevention if they are younger; have no predisposition to thromboembolic events such as stroke, pulmonary embolism, or deep venous thrombosis; or do not have a uterus.

Table 1. Predicted Benefits and Harms of 5 Years of Tamoxifen Therapy according to Age and Family History^1^

Variable^2^ | Women 45 Years of Age | Women 55 Years of Age | Women 65 Years of Age | Women 75 Years of Age
Predicted 5-year risk of breast cancer, %^3^
No Family history | 0.7 | 1.1 | 1.5 | 1.6
Family history | 1.6 | 2.3 | 3.2 | 3.4
Benefits per 1,000 women over 5 y of tamoxifen therapy
Cases of invasive breast cancer avoided, n
No Family history | 3-4 | 5-6 | 7-8 | 8
Family history | 8 | 11-12 | 16 | 17
Cases of noninvasive breast cancer avoided, n
No Family history | 1-2 | 2 | 2-3 | 2-3
Family history | 2-3 | 3-4 | 4-5 | 5-6
Hip fractures avoided, n ^4^ | <1 | 3 | 5 | 15
Harms per 1000 women over 5 y of tamoxifen therapy
Cases of endometrial cancer caused, n ^4^ | 1-2 | 12 | 21 | 22
Strokes caused, n ^4^ | 1 | 3 | 9 | 20
Pulmonary emboli caused, n ^4^ | 1-2 | 4-5 | 9 | 18
Cases of deep venous thrombosis caused, n ^4^ | 1-2 | 1-2 | 3 | 4

^1^ These estimates are based on the Gail model, outcomes from the Breast Cancer Prevention Trial, and baseline rates of harms from Gail et al.^13 (http://www.ahrq.gov/clinic/3rduspstf/breastchemo/breastchemorr.htmbreastchemorr.htm#ref13)^

^2^ No family history = no first-degree relatives with breast cancer; family history = 1 first-degree relative with breast cancer.

^3^ Based on menarche at 12 years of age, first birth at 22 years of age, and no history of breast biopsy, as calculated from the Gail model.

^4^ Modified from Gail et al.^13 (http://www.ahrq.gov/clinic/3rduspstf/breastchemo/breastchemorr.htm#ref13)^

- In general, the balance of benefits and harms of chemoprevention is more favorable for:
  1. Women in their 40s who are at increased risk for breast cancer and have no predisposition to thromboembolic events.
  2. Women in their 50s who are at increased risk for breast cancer, have no predisposition to thromboembolic events, and do not have a uterus.
  For example, a woman who is 45 years of age and has a mother, sister, or daughter with breast cancer would have approximately a 1.6 percent risk for developing breast cancer over the next 5 years (Table 1). On average, treating such women with tamoxifen for 5 years would prevent about three times as many invasive cancers (8 per 1,000) as the number of serious thromboembolic complications caused (1 stroke and 1 to 2 pulmonary emboli per 1,000). Among women 55 years of age, benefits exceed harms only for those who are not at risk for endometrial cancer; and the margin of benefit is small unless risk for breast cancer is substantially increased (for example, 4 percent over 5 years).

- Women younger than 40 years of age have a lower risk for breast cancer, and thus will not experience as large an absolute benefit from breast cancer chemoprevention as older women. Women 60 years of age and older, who have the highest risk for breast cancer also have the highest risk for complications from chemoprevention with a less favorable balance of benefits and harms.

- The USPSTF found more evidence for the benefits of tamoxifen than for the benefits of raloxifene. Currently, only tamoxifen is approved by the U.S. Food and Drug Administration (FDA) for the specific indication of breast cancer chemoprevention. Although there are biological reasons to suspect that raloxifene should have similar benefits, trial data currently are limited to one study in which the primary outcome was fracture prevention. Additional trials to further evaluate this drug's efficacy for breast cancer chemoprevention are under way, including a trial comparing efficacy and safety of raloxifene and tamoxifen. Raloxifene is approved by the FDA for preventing and treating osteoporosis.