# Scientific Evidence

## Epidemiology and Clinical Consequences

Hormone replacement therapy is one of the most commonly prescribed drug regimens for postmenopausal women in the United States. Many women use HRT to treat symptoms of menopause, but publicity about the possible ability of HRT to prevent chronic conditions, such as osteoporosis, CHD, Alzheimer's disease, and colorectal cancer, has also contributed to the increase in HRT use over the past decade.

The median age of menopause in women in the United States is 51 years (range, 41 to 59 years), but ovarian production of estrogen and progestin begins to decrease years before the complete cessation of menses. Lower levels of circulating estrogen contribute to the accelerated bone loss and increased low‐density lipoprotein levels that occur around menopause. The average woman in the U.S. who reaches menopause has a life expectancy of nearly 30 years. The probability that a menopausal woman will develop various chronic diseases over her lifetime has been estimated to be 46 percent for CHD, 20 percent for stroke, 15 percent for hip fracture, 10 percent for breast cancer, and 2.6 percent for endometrial cancer.^4^ In North America, an estimated 7‐8 percent of people 75 to 84 years of age have dementia, and postmenopausal women have a 1.4‐ to 3.0‐fold higher risk for Alzheimer's disease than do men. The lifetime risk for developing colorectal cancer for a woman in the United States is 6 percent, with more than 90 percent of cases occurring after 50 years of age.^5^ Many of these causes of morbidity in older women appear to be influenced by estrogen or progestin.

Osteoporosis affects a large proportion of postmenopausal women in the United States, and the prevalence of osteoporosis increases steadily with age. In the postmenopausal period, decline of estrogen production is associated with reduction of bone mineral density. Bone density is estimated to decrease by 2 percent each year during the first 5 years after menopause, followed by an annual loss of approximately 1 percent for the rest of a woman's life. On the basis of commonly used criteria, up to 70 percent of women older than 80 years of age have osteoporosis.

## Benefits of Hormone Replacement Therapy

Osteoporosis and Fractures

Low bone density is associated with an increased risk for osteoporotic fractures. Good evidence from observational studies and randomized clinical trials demonstrate that estrogen therapy increases bone density and reduces risk for fractures. Good evidence from many randomized clinical trials has demonstrated that HRT increases bone density at the hip, the lumbar spine, and peripheral sites.

A meta‐analysis of 22 trials of estrogen reported an overall 27 percent reduction in nonvertebral fractures (relative risk [RR], 0.73; 95 percent CI, 0.56 to 0.94), although the quality of individual studies varied.^6^ Observational studies have also demonstrated reductions in fractures of the vertebrae (RR for ever use, 0.6; 95 percent CI, 0.36 to 0.99), wrist (RR for current use, 0.39; 95 percent CI, 0.24 to 0.64), and possibly hip (RR for current use, 0.64; 95 percent CI, 0.32 to 1.04) among women taking HRT.

The Heart and Estrogen/Progestin Replacement Study (HERS and its unblinded followup study, HERS II),^7^ a trial of combined estrogen and progestin (CEE/MPA) for the secondary prevention of heart disease that reported many other outcomes, found no reduction in hip, wrist, vertebral, or total fractures with hormone therapy (relative hazard [RH] for total fractures, 1.04; 95 percent CI, 0.87 to 1.25).

The WHI^3^ found significant reductions in total fracture risk (RH, 0.76; 95 percent CI, 0.63 to 0.92) among healthy women taking estrogen and progestin. The WHI also reported reductions for hip (RH, 0.66; 95 percent CI, 0.33 to 1.33) and vertebral fracture (RH, 0.66; 95 percent CI, 0.32 to 1.34), although these did not achieve statistical significance in adjusted analyses.^3^ The WHI reported both nominal and adjusted confidence intervals. The USPSTF relied on nominal confidence intervals for the primary outcomes of breast cancer and CHD and adjusted confidence intervals for other secondary outcomes. The USPSTF concluded that there was good evidence that HRT increases bone mineral density and fair‐to‐good evidence that it reduces fractures.

Colorectal Cancer

A meta‐analysis of 18 observational studies of postmenopausal women reported a 20 percent reduction in cancer of the colon (RR, 0.80; 95 percent CI, 0.74 to 0.86) and a 19 percent reduction in cancer of the rectum (RR, 0.81; 95 percent CI, 0.72 to 0.92) among women who had ever used HRT.^8^ This decrease in risk was more apparent when current users were compared with those who had never used HRT (RR, 0.66; 95 percent CI, 0.59 to 0.74). Comparable results from the WHI study were reported for women taking CEE/MPA (RH, 0.63; 95 percent CI, 0.32 to 1.24), and the HERS studies also found reduced incidence of colon cancer (RH, 0.8; 95 percent CI, 0.46 to 1.45). The USPSTF concluded that there was fair evidence that HRT reduces colorectal cancer incidence.

## Uncertain Benefits or Harms of Hormone Replacement Therapy

Cognition and Dementia

Nine randomized controlled trials examining the effect of HRT on cognition showed improvement in verbal memory, vigilance, reasoning, and motor speed among women who had menopausal symptoms but not among women who were asymptomatic at baseline. Because of heterogeneity and variation in assessment of outcomes among studies, meta‐analysis of these studies was not performed for the USPSTF.^2^ A meta‐analysis of 12 observational studies (1 of good quality, 3 of fair quality, and 8 of poor quality) showed a reduction in the risk for dementia among postmenopausal women taking HRT (RR, 0.66; 95 percent CI, 0.53 to 0.82).^9^ Neither the WHI nor HERS has yet reported effects of HRT on cognition and dementia, but other ongoing trials are examining the effects of HRT on these endpoints. Given the methodologic limitations of the available studies and the potential for confounding or selection bias, the USPSTF concluded that there is insufficient evidence to determine whether HRT reduces the risk for dementia or cognitive dysfunction in otherwise healthy women.

## Harms of Hormone Replacement Therapy

Breast Cancer

Because breast tissue is sensitive to reproductive hormones, there has been long‐standing concern about breast cancer risk among women who take HRT. The estrogen and progestin arm of the WHI study was recently terminated because of an increased breast cancer incidence (RH, 1.26; 95 percent CI, 1.00 to 1.59).^3^ However, no effect on breast cancer mortality was observed. Comparable increases in breast cancer incidence were observed among women taking estrogen and progestin over 6.8 years of followup in the HERS studies (RH, 1.27; 95 percent CI, 0.84 to 1.94).^7^ Although many good observational studies on breast cancer and meta‐analyses of these studies have been conducted, the conclusions are limited by:

- Healthy‐user bias.
- Variations in specific preparations, dose, and duration of estrogen and progestin therapy.
- Differences in the ways in which breast cancer end points were ascertained.

In the aggregate, breast cancer incidence is slightly increased for current (RR, 1.21 to 1.40) or long‐term (>5 years) users (RR, 1.23 to 1.35) compared with nonusers.^2^ ^,^ ^10^ ^,^ ^11^ However, there seems to be no effect on or decreased breast cancer mortality in ever‐ or short‐term users (RR, 0.5 to 1.0).^11^ The effects of long‐term HRT use on breast cancer mortality in two good‐quality cohort studies are conflicting.^12^ ^,^ ^13^ Whether the combination of estrogen and progestin confers a greater risk than estrogen alone is unknown; WHI investigators have reported that no increase in breast cancer has been observed after 5 years of followup in the ongoing study of unopposed estrogen in women who have had a hysterectomy.

The USPSTF concluded that there was fair‐to‐good evidence that HRT increases the incidence of breast cancer (with best evidence for estrogen plus progestin), but its effects on breast cancer mortality are uncertain.

Coronary Heart Disease

Coronary heart disease remains the leading cause of death among women. Hormone replacement therapy has diverse effects on lipid levels, endothelial wall function, blood pressure, coagulation factors, weight, and inflammation (for example, C‐reactive protein). In the WHI study, women who took CEE/MPA daily had an increased risk for CHD (fatal and non‐fatal myocardial infarctions), which was evident shortly after initiation of the study (RH, 1.29; 95 percent CI, 1.02 to 1.63). Coronary heart disease mortality was not significantly increased (RH, 1.18; 95 percent CI, 0.70 to 1.97). Meta‐analysis of observational studies showed a statistically significant reduction in CHD (RR, 0.80; 95 percent CI, 0.68 to 0.95) among current HRT users, but not among ever or past users, compared with women who had never taken HRT (nonusers).^2^ ^,^ ^14^ However, among studies that controlled for socioeconomic status (social class, education, or income), no benefit was seen among current HRT users (RH, 0.97; 95 percent CI, 0.82 to 1.16), suggesting that the observed difference may be due to confounding by socioeconomic status and other lifestyle factors (e.g., exercise, alcohol use) rather than use of HRT. Coronary heart disease mortality in observational studies is reduced among current HRT users (RR, 0.62; 95 percent CI, 0.40 to 0.90) but is not reduced among ever, past, or all users. Thus, selection bias (the tendency of healthier women to use HRT) appears to explain the apparent protective effect of estrogen on CHD seen in observational studies.

The USPSTF concluded that HRT does not decrease, and may in fact increase, the incidence of CHD. The effects of HRT on CHD mortality, however, are less certain.

Stroke

A meta‐analysis of nine observational primary prevention studies suggests that HRT use is associated with a small increase in stroke incidence (RR, 1.12; 95 percent CI, 1.01 to 1.23), due primarily to an increase in thromboembolic stroke (RR, 1.20; 95 percent CI, 1.01 to 1.40).^14^ ^,^ ^15^ The risk for subarachnoid bleeding and hemorrhagic stroke was not increased, and the overall stroke mortality was marginally reduced (RR, 0.81; 95 percent CI, 0.71 to 0.92). These results are consistent with findings from the estrogen and progestin arm of the WHI, which reported increased incidence of stroke in women taking CEE/MPA daily (RH, 1.41; 95 percent CI, 0.86 to 2.31). Two secondary prevention trials,^16^ ^,^ ^17^ which were not included in the USPSTF review of HRT for primary prevention, reported no clear effect of HRT on stroke incidence, but stroke mortality was increased in women with a previous stroke.^17^

The USPSTF concluded that there is fair evidence that HRT increases the risk for stroke.

Venous Thromboembolism (Deep Venous Thrombosis and Pulmonary Embolism)

In a meta‐analysis of 12 studies (3 randomized, controlled trials; 8 case‐control studies; and 1 cohort study), HRT was associated with an increased risk for venous thromboembolism (RR, 2.14; 95 percent CI, 1.64 to 2.81).^18^ ^,^ ^19^ Five of six studies that examined the effects of HRT over time reported that the risk was highest within the first year of use (RR, 3.49; 95 percent CI, 2.33 to 5.59). These results are consistent with the findings in the estrogen and progestin arm of the WHI, which reported a 2‐fold increased rate of venous thromboembolic disease (RH, 2.11; 95 percent CI, 1.26 to 3.55), including deep venous thrombosis and pulmonary embolism, in women taking CEE/MPA daily.

The USPSTF concluded that there is good evidence that HRT increases the risk for venous thromboembolism.

Endometrial and Ovarian Cancer

Results of a previously published meta‐analysis of 29 good‐quality observational studies of endometrial cancer reported a relative risk of 2.3 (95 percent CI, 2.1 to 2.5) for users of unopposed estrogen compared with nonusers.^20^ Risks increased with increasing duration of use (RR, 9.5 for 10 years of use). The risk for endometrial cancer remained elevated 5 or more years after discontinuation of unopposed estrogen therapy in these studies. With combined estrogen‐progestin regimens, cohort studies showed a decreased risk for endometrial cancer (RR, 0.4; 95 percent CI, 0.2 to 0.6) compared with nonusers, but case‐control studies showed an increase in risk (odds ratio [OR], 1.8; 95 percent CI, 1.1 to 3.1). Estrogen and progestin did not increase the risk for endometrial cancer in HERS (RH, 0.25; 95 percent CI, 0.05 to 1.18)^6^ or in the WHI (RH, 0.83; 95 percent CI, 0.29 to 2.32).

The USPSTF concluded that unopposed estrogen, but not combined estrogen‐progestin therapy, increases risk for endometrial cancer.

Data on the association between the use of HRT and the risk for ovarian cancer are inconsistent. Results of case‐control studies have been mixed, but two good‐quality cohort studies reported increased risks (RR, 1.8 to 2.2) for ovarian cancer or ovarian cancer mortality among women who had taken HRT for 10 years or more^21,^ ^22^. A third study found no effect of HRT on ovarian cancer mortality.^23^ One study suggested higher risk with unopposed estrogen than with estrogen‐progestin therapy,^21^ but data are insufficient to resolve the effects of different formulations or doses of HRT on ovarian cancer risk. Neither the WHI nor HERS has reported risk for ovarian cancer.

The USPSTF concluded that evidence was insufficient to determine the effect of HRT on ovarian cancer.

Cholecystitis

Many but not all studies have reported an association between HRT and gallbladder disease. Results from a good‐quality cohort study, the Nurses' Health Study, reported an increase in risk for cholecystitis among current HRT users (RR, 1.8; 95 percent CI, 1.6 to 2.0) and long‐term users (>5 years) (RR, 2.5; 95 percent CI, 2.0 to 2.9) compared with nonusers.^24^ Risk for cholecystitis remained elevated among past users. An increase in biliary tract surgery during 6.8 years of followup was reported among women taking estrogen plus progestin compared with those taking placebo (RR, 1.48; 95 percent CI, 1.12 to 1.95) in HERS^7^ ^,^ ^25^; the WHI has not reported biliary tract outcomes.

The USPSTF concluded that there is fair evidence that HRT increases the risk for cholecystitis.