# Clinical Considerations

- Although the USPSTF concludes that the harms of estrogen‐progestin therapy are likely to outweigh the chronic disease prevention benefits for most women, the absolute increase in risk from HRT is modest. Some women, depending on their risk characteristics and personal preferences, might decide that the benefits of taking HRT outweigh the potential harms. Based on results reported from the WHI study^3^ for women aged 50 to 79 years (average age, 63 years), 10,000 women taking estrogen and progestin for 1 year might experience 7 additional CHD events, 8 more strokes, 8 more pulmonary emboli, and 8 more invasive breast cancers, but would also have 6 fewer cases of colorectal cancer and 5 fewer hip fractures.
- Clinicians should develop a shared decisionmaking approach to preventing chronic diseases in perimenopausal and postmenopausal women. This approach should consider individual risk factors and preferences in selecting effective interventions for reducing the risks for fracture, heart disease, and cancer. Clinicians should discuss with patients other effective strategies for preventing osteoporosis and fractures. See other USPSTF recommendations:
- Screening for Postmenopausal Osteoporosis (http://www.ahrq.gov/clinic/uspstf/uspsoste.htm).
- Screening for High Blood Pressure (http://www.ahrq.gov/clinic/uspstf/uspshype.htm).
- Screening Adults for Lipid Disorders (http://www.ahrq.gov/clinic/uspstf/uspspmho.htm).
- Counseling to Prevent Tobacco Use (http://www.ahrq.gov/clinic/uspstf/uspstbac.htm).
- Counseling to Promote a Healthy Diet (http://www.ahrq.gov/clinic/uspstf/uspsdiet.htm).
- Counseling to Promote Physical Activity (http://www.ahrq.gov/clinic/uspstf/uspsphys.htm).
- Screening for Breast Cancer (http://www.ahrq.gov/clinic/uspstf/uspsbrca.htm).
- Screening for Colorectal Cancer (http://www.ahrq.gov/clinic/uspstf/uspscolo.htm).
- The USPSTF did not consider the use of HRT for the management of menopausal symptoms. Decisions to initiate or continue HRT for menopausal symptoms should be made on the basis of discussions between a woman and her clinician. Women should be informed that there are some risks (such as the risk for venous thromboembolism, CHD, and stroke) within the first 1 to 2 years of therapy, whereas other risks (such as the risk for breast cancer) appear to increase with longer‐term HRT. Other expert groups have recommended that women who decide to take HRT for the relief of menopausal symptoms use the lowest effective dose for the shortest possible time.
- The quality of evidence on the benefits and harms of HRT varies for different hormone regimens. Other than the two large randomized controlled trials of daily conjugated equine estrogen (CEE) and medroxyprogestrone acetate (MPA), most of the evidence on HRT comes from observational studies that did not differentiate among the effects of specific hormone preparations.^3^ ^,^ ^4^ Until data indicate that other HRT regimens have a favorable balance of benefits to harms, a cautious approach would be to avoid using HRT routinely for the specific purpose of preventing chronic disease in women.
- Evidence is inconclusive to determine whether phytoestrogens (isoflavones such as iproflavone, which are found in soy milk, soy flour, tofu, and other soy products) are effective for reducing the risk for osteoporosis or cardiovascular disease (USPSTF, unpublished data, 2002).