# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Bader JD, Lohr KN, Frame PS. Physicians' roles in preventing dental caries in preschool children: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004;26:315-25. [pmid: 15110059].
3 Bader JD, Rozier G, Harris R, Lohr KN. Dental Caries Prevention: The Physician's Role in Child Oral Health. Systematic Evidence Review. Systematic Evidence Review No. 29 (Prepared by the Research Triangle Institute‐University of North Carolina Evidence‐based Practice Center under Contract No. 290‐97‐0011). Rockville, MD: Agency for Healthcare Research and Quality. April 2004. (Available on the AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm.)
4 Edelstein BL. Evidence‐based dental care for children and the age 1 dental visit. Pediatr Ann. 1998;27(9):569-74. [pmid: 9778708].
5 Vargas CM, Crall JJ, Schneider DA. Sociodemographic distribution of pediatric dental caries: NHANES III, 1988‐1994. J Am Dent Assoc. 1998;129(9):1229-38. [pmid: 9766104].
6 American Academy of Pediatric Dentistry. Guidelines: Infant oral health care. Available at http://www.aapd.org/members/referencemanual/pdfs/02‐03/G_InfantOralHealth.pdf (http://www.aapd.org/members/referencemanual/pdfs/02-03/G_InfantOralHealth.pdf). Accessed: February 17, 2004.
7 American Academy of Pediatric Dentistry. Guidelines for Fluoride Therapy Reference Manual, 2000‐2001.
8 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta‐analysis. Community Dent Oral Epidemiol. 1999;27(1):48-56. [pmid: 10086926].
9 Public Health Service Committee to Coordinate Environmental Health and Related Programs. Review of fluoride: benefits and risk. Washington, DC: U.S. Department of Health and Human Services, Public Health Service; 1991.
10 Rozier RG. The prevalence and severity of enamel fluorosis in North American children. J Public Health Dent. 1999;59(4):239-46. [pmid: 10682330].
11 Pendrys DG. Risk of enamel fluorosis in nonfluoridated and optimally fluoridated populations: considerations for the dental professional. J Am Dent Assoc. 2000;131(6):746-55. [pmid: 10860326].
12 Lewis CW, Grossman DC, Domoto PK, Deyo RA. The role of the pediatrician in the oral health of children: A national survey. Pediatrics. 2000;106(6):E84. [pmid: 11099627].
13 Rozier RG. Effectiveness of methods used by dental professionals for the primary prevention of dental caries. J Dent Educ. 2001;65(10):1063-72. [pmid: 11699978].
14 Bader J. Risk assessment in dentistry: proceedings of a conference. University of North Carolina Department of Dental Ecology; 1990.
15 Horowitz AM, Selwitz RH, Kleiman DV, Ismail AI, Bader JD. NIH Consensus Development Conference on Diagnosis and Management of Dental Caries Throughout Life. J Dent Educ. 2001;10:940-1179.
16 Sgan‐Cohen HD, Mansbach IK, Haver D, Gofin R. Community‐oriented oral health promotion for infants in Jerusalem: evaluation of a program trial. J Public Health Dent. 2001;61(2):107-13. [pmid: 11474913].
17 Brown LF. Research in dental health education and health promotion: a review of the literature. Health Educ Q. 1994;21(1):83-102. [pmid: 8188495].
18 Kay EJ, Locker D. Is dental health education effective? A systematic review of current evidence. Community Dent Oral Epidemiol. 1996;24(4):231-35. [pmid: 8871028].
19 Kay E, Locker D. A systematic review of the effectiveness of health promotion aimed at improving oral health. Community Dent Health. 1998;15(3):132-44. [pmid: 10645682].
20 Sprod AJ, Anderson R, Treasure E. Effective oral health promotion. Health Promotion Wales; 1996; Technical Report 20.