# References

1 Guise J-M, Mahon SM, Aickin M, Helfand M, Peipert JF, Westhoff C. Screening for bacterial vaginosis in pregnancy. Am J Prev Med. 2001;20:62-72. [pmid: 11306234].
2 Guise J-M, Mahon S, Aickin M, Helfand M. Screening for bacterial vaginosis in pregnancy. Systematic evidence review. Pub. No. AHRQ01-S001. Rockville, MD: Agency for Healthcare Research and Quality. 2001. [pmcid: 320826].
3 Centers for Disease Control and Prevention. 1998 guidelines for treatment of sexually transmitted diseases. MMWR Morb Mort Wkly Rep. 1998;47:70-4.
4 Bacterial vaginosis screening for prevention of preterm delivery. Committee Opinion No. 198. Washington, DC: American College of Obstetricians and Gynecologists; February 1998.
5 Brocklehurst P, Hannah M, McDonald H. Interventions for treating bacterial vaginosis in pregnancy (Cochrane Review). In: The Cochrane Library, 4, 2000. Oxford: Update Software. Available at http://hiru.mcmaster.ca/cochrane.