# Recommendations of Others

Guidelines of the American Academy of Pediatrics can be accessed at: http://www.aap.org/policy/fluoride.html

Guidelines of the Centers for Disease Control and Prevention can be accessed at: http://www.cdc.gov/mmwr/PDF/RR/RR5014.pdf

Guidelines of the American Dental Association can be accessed at: http://www.ada.org/prof/resources/positions/statements/index.asp

Guidelines of the Canadian Task Force on Preventive Health Care can be accessed at: http://www.ctfphc.org

Guidelines of the American Academy of Family Physicians can be accessed at: http://www.aafp.org/x6827.xml