# Discussion

Dental caries is a common childhood disease: as many as 19 percent of children aged 2 to 5 years and 52 percent of children aged 5 to 9 years have experienced dental caries.^4,^ ^5^ Minority and economically disadvantaged children have a higher prevalence and severity of caries compared with other groups.^3^ Untreated caries in primary teeth may lead to caries in permanent teeth and a possible loss of arch space.^3^

Although a first dental visit is recommended when a child is approximately 1 year old,^6^ only 36 percent of 2‐ to 4‐year‐olds have had a dental visit in the past year; thus, primary care clinicians have a role in providing access to preventive dental services, particularly for very young and disadvantaged children.^5^

The USPSTF reviewed the evidence for the prevention and management of dental caries in children up to 5 years of age. The review did not cover the evidence for water fluoridation, application of dental sealants, or prenatal counseling. However, based on strong evidence, the Centers for Disease Control and Prevention Task Force on Community Preventive Services has recommended that local water fluoridation be a part of a population‐based strategy for the prevention of tooth decay in communities. The recommendation can be accessed at www.thecommunityguide.org/oral/.

Clinical trials that assess the effectiveness of oral fluoride supplementation started before the age of 5 in preventing dental caries have consistently found that fluoride supplementation prevents 32 percent to 81 percent of caries lesions in primary teeth or tooth surfaces.^3^ The smallest proportional reductions occurred in studies with the highest background water fluoride level, which is a level that is not currently considered appropriate for supplementation.^7^ Since these trials have several limitations, the overall strength of evidence is considered fair by the USPSTF, and these results should be generalized with caution.^3^ Although only 2 studies with mixed results have examined the effectiveness of fluoride supplementation on preventing caries in permanent teeth in preschool children, a larger body of evidence supports the effectiveness of fluoride supplementation in school‐aged children to prevent caries in permanent teeth.^3^

Dental fluorosis is a potential harm of oral fluoride supplementation. A systematic review concluded that the use of fluoride supplements increases the risk for dental fluorosis, although the fluorosis is very mild (as classified by Dean's Fluorosis Index) in the large majority of children.^8^ A national survey in the United States found that the prevalence of fluorosis in the permanent teeth of children aged 5 to 17 years was nearly 24 percent; almost all cases were mild.^9^ About 13 percent and 28 percent of children who were continuous residents of nonfluoridated and fluoridated communities, respectively, had very mild fluorosis.^9^ The prevalence of dental fluorosis considered to be of some aesthetic consequence in children varies from 3 percent to 7 percent.^10^ One study estimated that nearly two‐thirds of cases of dental fluorosis observed in communities in Massachusetts and Connecticut were attributable to supplementation using pre‐1994 dosage schedules; the remaining cases were attributed to early use of fluoride toothpaste.^11^

Although the studies assessing the appropriateness of primary care clinicians' prescription of fluoride supplements have problems that compromise external and internal validity, they indicate that the majority of physicians, especially pediatricians, prescribe oral fluoride supplements to at least some of their patients.^3^ Since not all physicians report that they know the fluoride status of their patients or the fluoridation level of their patients' water supplies, there is the possibility of inappropriate prescription of fluoride supplements that may lead to excessive fluoride intake.

Professional topical fluoride application is an adjunct to oral fluoride supplementation used for the prevention of dental caries. It offers the advantages of ease of use, patient acceptance, and reduced potential for toxicity.^3^ Adoption of fluoride varnish by primary care clinicians is in the early stages in the United States, although it is commonly used in dentistry in Europe. One study reported that only 22 percent of pediatricians were familiar with fluoride varnish.^12^ Four of 6 trials, including 3 randomized controlled trials, found statistically significant reductions in the number of tooth surfaces with cavitated lesions in children younger than 5 years who had fluoride varnish applied to their primary teeth, compared with untreated controls.^3^,^13^ These trials tested 2 fluoride varnishes: 2.3 percent F (Duraphat®) and 0.1 percent F (Fluor Protector®). Since only a small amount of varnish is applied, the total amount of active agent administered to the patient is markedly reduced compared with other fluoride applications, potentially decreasing the risk for dental fluorosis.

The number of risk indicators for dental caries is large,^14,^ ^15^ and subsets of these have been suggested for use in dental practice. Risk indicators most accessible for primary care clinicians' screening of preschool children are the presence of caries lesions, plaque retention, and the presence of white spots or other evidence of demineralization, such as discolored pits and fissures of teeth.^3^ Only 2 case studies assess the accuracy of oral examinations conducted by primary care clinicians to screen children for dental caries.^3^ Although the sensitivity and specificity of oral examinations in these studies were high—92 percent and 100 percent and 87 percent and 99 percent, respectively—there are substantial concerns about the external validity of these studies. The risk indicators or combinations of indicators currently advocated for use have not been validated individually. Only 1 study (of poor quality) has examined the effectiveness of early counseling on caries prevention by primary care clinicians. The study showed that counseling parents with infants 6 to 12 months of age is essentially ineffective with respect to use of the bottle and minimally effective with respect to tooth brushing.^16^ Four systematic reviews show that improved knowledge does not translate into long‐term changes in oral health behaviors.^17^‐^20^ Although oral health behaviors, principally oral hygiene, can be changed by a variety of interventions, the most effective strategy appears to be personal one‐on‐one attention with active involvement.^3^ The interventions targeting oral health behaviors tended to be effective in the short term, but with little or no long‐term effects. Almost all behavioral change interventions associated with any dental caries prevention included the adoption and increase of fluoride use.^3^

There are several gaps in evidence on the prevention of dental disease in young children. No relevant studies have examined the effectiveness of primary care clinicians in securing parental adherence to daily fluoride supplementation. No studies have been published on the risk for dental fluorosis resulting from the use of fluoride varnish. No relevant studies have assessed the accuracy of screening by primary care clinicians to identify children at elevated risk for dental caries. Little research (only 1 case study with substantial methodological problems) examines the effectiveness of primary care clinicians in referring children to a dentist. Limited evidence supports the effectiveness of oral health education or interventions designed to improve oral hygiene in the prevention of dental caries. No research assesses the effectiveness of a primary care clinician‐supplied parental counseling intervention in preventing dental caries.