# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd edition. Washington, DC: Office of Disease Prevention and Health Promotion, U.S. Government Printing Office; 1996.
2 Wilson PW, D'Agostino RB, Levy D, Belanger AM, Sibershatz H, Kannel WB. Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97(18):1837-47. [pmid: 9603539].
3 Hoyert DL, Kochanek KD, Murphy SL. Deaths: Final Data for 1997. National Vital Statistics Reports. Hyattsville, MD: National Center for Health Statistics; 1999.
4 Collaborative overview of randomised trials of antiplatelet therapy—I: Prevention of death, myocardial infarction, and stroke by prolonged antiplatelet therapy in various categories of patients. Antiplatelet Trialists' Collaboration BMJ 1994 308 81 106 8298418 2539220
5 Final report on the aspirin component of the ongoing Physicians' Health Study. Steering Committee of the Physicians' Health Study Research Group N Engl J Med 1989 321 129 35 2664509
6 Peto R, Gray R, Collins R, Wheatley K, Hennekens C, Jamrozik K. Randomised trial of prophylactic daily aspirin in British male doctors. Br Med J (Clin Res Ed). 1988;296:313-6. [pmid: 3125882].
7 Thrombosis prevention trial: randomised trial of low‐intensity oral anticoagulation with warfarin and low‐dose aspirin in the primary prevention of ischemic heart disease in men at increased risk. The Medical Research Council's General Practice Research Framework Lancet 1998 351 233 41 9457092
8 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood pressure lowering and low‐dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. 1998;280:1930-5.
9 Collaborative Group of the Primary Prevention Project (PPP). Low‐dose aspirin and vitamin E in people at cardiovascular risk: a randomized trial in general practice Lancet 2001 357 89 95 11197445
10 Roderick PJ, Wilkes HC, Meade TW. The gastrointestinal toxicity of aspirin: an overview of randomised controlled trials. Br J Clin Pharmacol. 1993;35:219-26. [pmid: 8471398]. [pmcid: 1381566].
11 Dickinson JP, Printice CR. Aspirin: benefit and risk in thromboprophylaxis. QJM. 1998;91:523-38. [pmid: 9893756].
12 Stalnikowicz‐Darvasi R. Gastrointestinal bleeding during low‐dose aspirin administration for prevention of arterial occlusive events. J Clin Gastroenterol. 1995;21:13-6. [pmid: 7560825].
13 Anderson G. Acetylsalicylic acid and the primary prevention of cardiovascular disease. In: Canadian Task Force on the Periodic Health Examination. Ottawa (Canada): Health Canada; 1994: 680‐90.
14 Aspirin Therapy in Diabetes. American Diabetes Association. Diabetes Care 2001;24(suppl 10):S62‐S63. Available at: http://www.diabetes.org/clinicalrecommendations/Supplement101/S62.htm. Accessed May 25, 2001.
15 Hennekens CH, Dyken ML, Fuster V. Aspirin as a therapeutic agent in cardiovascular disease: a statement for healthcare professionals from the American Heart Association. Circulation. 1997;96:2751-3. [pmid: 9355934].
16 Prevention of coronary heart disease in clinical practice. Recommendations of the Second Joint Task Force of European and other Societies in coronary prevention Eur Heart J 1998 19 10 1434 1503 9820987