# Recommendations of Others

In 1994, the Canadian Task Force on Preventive Health Care concluded that the evidence was not strong enough to recommend for or against use of aspirin for primary prevention of heart disease in men or women and recommended that physicians and patients balance the reduced rate of nonfatal myocardial infarction against potential adverse effects.^13^ In 2000, the American Diabetes Association recommended that clinicians consider aspirin for primary prevention of heart disease in diabetic patients who are older than 30 years or have risk factors for cardiovascular disease and no contraindications to aspirin therapy.^14^ In 1997, the American Heart Association concluded that aspirin may be warranted for patients at high risk of myocardial infarction but that health care providers must consider a patient's particular cardiovascular risk profile, the demonstrated benefits of aspirin on reducing risk for a first myocardial infarction, and known as well an unknown side effects of aspirin.^15^

In 1998, the European Society of Cardiology recommended low‐dose aspirin (75 mg) for patients with well‐controlled hypertension and men at "particularly" high risk for coronary heart disease, but not for all individuals at high risk.^16^