# Scientific Evidence

## Epidemiology and Clinical Background

Cardiovascular disease, including ischemic coronary heart disease, stroke, and peripheral vascular disease, is the leading cause of death in the United States.^3^ Yearly, over 1 million Americans experience new or recurrent myocardial infarction or fatal coronary heart disease. Most events occur in older people and those with recognized risk factors for cardiovascular disease, including high cholesterol, high blood pressure, diabetes, or a history of smoking.

The early‐documented and clear success of aspirin in preventing further clinical disease in some patients with known heart disease (secondary prevention) raised interest in aspirin as a potential primary preventive intervention in men and women without known heart disease.^4^ Two early randomized trials of aspirin had conflicting results, however, and lacked sufficient power to estimate major harms, such as gastrointestinal bleeding and hemorrhagic stroke.^5,^ ^6^ Thus, the role of aspirin in primary prevention has remained controversial. The new USPSTF recommendation incorporates additional data from three recent trials and provides more reliable estimates of both benefits and harms of aspirin in patients without known heart disease.

## Efficacy of Chemoprevention

Five trials have examined the effects of daily or every‐other‐day aspirin for the primary prevention of cardiovascular events over periods of 4 to 7 years.^5^‐^9^ Most participants were men older than 50 years. Meta‐analysis of pooled data from all of the studies showed that aspirin therapy reduced the risk for CHD by 28 percent (summary odds ratio [OR], 0.72; 95 percent CI, 0.60 to 0.87). Summary estimates showed no significant effects of aspirin on total mortality (OR, 0.93; 95 percent CI, 0.84 to 1.02) and stroke (OR, 1.02; 95 percent CI, 0.85 to 1.23).

## Harms of Chemoprevention

These five primary prevention trials, and a larger number of randomized controlled trials (RCTs) of secondary prevention that enrolled patients with heart disease or stroke, demonstrate that aspirin increases rates of gastrointestinal bleeding. Estimated rates of major gastrointestinal bleeding episodes are approximately 2 to 4 per 1,000 middle‐aged individuals (4 to 12 for older individuals) given aspirin for 5 years.^10^‐^12^

These controlled trials in primary and secondary prevention settings also suggest that aspirin increases rates of hemorrhagic strokes by a small amount (0‐2 per 1,000 individuals given aspirin for 5 years).5‐7 Such estimates are less reliable than those of gastrointestinal bleeding because few strokes were reported in the trials.