# Clinical Considerations

- Decisions about aspirin therapy should take into account overall risk for coronary heart disease. Risk assessment should include asking about the presence and severity of the following risk factors: age, sex, diabetes, elevated total cholesterol levels, low levels of high‐density lipoprotein (HDL) cholesterol, elevated blood pressure, family history (in younger adults), and smoking. Tools that incorporate specific information on multiple risk factors provide more accurate estimation of cardiovascular risk than categorizations based simply on counting the numbers of risk factors (http://www.intmed.mcw.edu/clincalc/heartrisk.html).^2^
- Men older than 40 years, postmenopausal women, and younger people with risk factors for coronary heart disease (eg, hypertension, diabetes, or smoking) are at increased risk for heart disease and may wish to consider aspirin therapy. Table 1 (http://www.ahrq.gov/clinic/3rduspstf/aspirin/asptab1.htm) shows how estimates of the type and magnitude of benefits and harms associated with aspirin therapy vary with an individual's underlying risk for coronary heart disease. Although balance of benefits and harms is most favorable in high‐risk people (5‐year risk greater than 3 percent), some people at lower risk may consider the potential benefits of aspirin to be sufficient to outweigh the potential harms.
- Discussions about aspirin therapy should focus on potential coronary heart disease benefits, such as prevention of myocardial infarction, and potential harms, such as gastrointestinal and intracranial bleeding. Discussions should take into account individual preferences and risk aversions concerning myocardial infarction, stroke, and gastrointestinal bleeding.
- Although the optimal timing and frequency of discussions related to aspirin therapy are unknown, reasonable options include every 5 years in middle‐aged and older people or when other cardiovascular risk factors are detected.
- Most participants in the primary prevention trials of aspirin therapy have been men between 40 and 75 years of age. Current estimates of benefits and harms may not be as reliable for women and older men.
- Although older patients may derive greater benefits because they are at higher risk for CHD and stroke, their risk for bleeding may be higher.
- Uncontrolled hypertension may attenuate the benefits of aspirin in reducing CHD.
- The optimum dose of aspirin for chemoprevention is not known. Primary and secondary prevention trials have demonstrated benefits with a variety of regimens, including 75 mg per day, 100 mg per day, and 325 mg every other day. Doses of approximately 75 mg per day appear as effective as higher doses; whether doses below 75 mg per day are effective has not been established. Enteric‐coated or buffered preparations do not clearly reduce adverse gastrointestinal effects of aspirin. Uncontrolled hypertension and concomitant use of other nonsteroidal anti‐inflammatory agents or anticoagulants increase risk for serious bleeding.