# References

1 Morris C, Carson S. Vitamin supplementation to prevent cardiovascular disease: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Int Med. 2003;139:56-70.
2 Ritenbaugh C, Streit K, Helfand M. Routine vitamin supplementation to prevent cancer: a summary of the evidence from randomized controlled trials for the U.S. Preventive Services Task Force. Available at: www.preventiveservices.ahrq.gov.
3 Shetty P, Atkins D. Routine vitamin supplementation to prevent cancer: update of evidence from randomized controlled trials, 1999‐2002. Available at: www.preventiveservices.ahrq.gov.
4 Pignone M, Ammerman A, Fernandez L, et al. Counseling to promote a healthy diet in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med 2003;24(1):75‐92.
5 U.S. Pharmacopeia Dietary Supplement Verification Program. Available at: http://www.usp‐dsvp.org/ (http://www.usp-dsvp.org/). Accessed April 30, 2002.
6 Screening for Neural Tube Defects. U.S. Preventive Services Task Force. Guide To Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996: 467‐483. Available at: http://www.ahrq.gov/clinic/uspstf/uspsneur.htm. Accessed May 8, 2003.
7 Steinmetz KA, Potter JD. Vegetables, fruit, and cancer prevention: a review. J Am Dietetic Assoc. 1996;96:1027-1039.
8 Ross RK. The pathogenesis of atherosclerosis: A perspective for the 1990s. Nature. 1993;362:801-809.
9 Diaz MN, Frei B, Vita JA, Keaney JF Jr. Antioxidants and atherosclerotic heart disease. N Engl J Med. 1997;337:408-416.
10 Zhang S, Hunter DJ, Forman MR, et al. Dietary carotenoids and vitamins A, C, and E and risk of breast cancer. J Nat Cancer Inst. 1999;1999:547-556.
11 Bostick RM, Potter JD, McKenzie DR, et al. Reduced risk of colon cancer with high intake of vitamin E: the Iowa Women's health Study. Cancer Res. 1993;53:4230-4237.
12 Kushi LH, Stampfer MJ, Prineas RJ, Mink PJ, Wu Y, Bostick RM. Dietary antioxidant vitamins and death from coronary heart disease in postmenopausal women. N Engl J Med. 1996;334:1156-1162.
13 Hunter DJ, Manson JE, Colditz GA, et al. A prospective study of the intake of vitamins C, E and A and the risk of breast cancer. N Engl J Med. 1993;1993:234-240.
14 The Alpha‐Tocopherol B‐CCPSG. The Effect of Vitamin E and beta‐carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med 1994 330 1029 1035
15 Enstrom JE, Kanim LE, Klein MA. Vitamin C intake and mortality among a sample of the United States population. Epidemiology. 1992;3:194-202. [pmcid: 444386].
16 Losonczy KG, Harris TB, Havlik RJ. Vitamin E and vitamin C supplement use and risk of all‐cause and coronary heart disease mortality in older persons: the Established Populations for Epidemiologic Studies of the Elderly. Am J Clin Nutr. 1996;64:190-196. [pmcid: 286146].
17 Kushi LH, Fee RM, Sellers TA, Zheng W, Folsom AR. Intake of vitamins A,C, and E and postmenopausal breast cancer. The Iowa Women's Health Study. Am J Epidemiol. 1996;144:165-174.
18 Yusuf S, Dagenais G, Pogue J, Bosch J, Sleight P. Vitamin E supplementation and cardiovascular events in high‐risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. 2000;2000:154-160.
19 Collaborative Group of the Primary Prevention Project. Low‐dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Lancet 2001 357 89 95
20 Omenn GS, Goodman GE, Thornquist MD, et al. Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med. 1996;1996:150-1155.
21 Hennekens CH, Buring JE, Manson JE, et al. Lack of effect of long‐term supplementation with beta‐carotene on the incidence of malignant neoplasms and cardiovascular disease. N Engl J Med. 1996;334:1145-1149.
22 Lee IM, Cook NR, Manson JE, Buring JE, Hennekens CH. Beta‐carotene supplementation and incidence of cancer and cardiovascular disease: The Women's Health Study. J Nat Cancer Inst. 1999;91:2102-2106.
23 Frieling U, Schaumberg D, Kupper T, Muntwyler J, Hennekens CH. A randomized, 12‐year primary ‐prevention trial of beta carotene supplementation for nonmelanoma skin cancer in the physician's health study. Arch Dermatolo. 2000;136:179-84. [pmcid: 218648].
24 Cook NR, Stampfer MJ, Ma J, et al. Beta‐carotene supplementation for patients with low baseline levels and decreased risks of total and prostate cancer. Cancer. 1999;86:1783-1792. [pmcid: 329809].
25 Omenn GS, Goodman GE, Thornquist MD, et al. Risk factors for lung cancer and for intervention effects in CARET, the Beta‐Carotene and Retinol Efficacy Trial. JNCI. 1996;88:1550-1559. [pmcid: 277451].
26 Greenberg ER, Baron JA, Karagas MR, et al. Mortality associated with low plasma concentration of beta carotene and the effect of oral supplementation. JAMA. 1996;275:699-703.
27 Rapola JM, Virtamo J, Haukka JK, et al. Effect of vitamin E and beta carotene on the incidence of angina pectoris. A randomized, double‐blind, controlled trial [published erratum appears in JAMA 1998 May 20;279(19):1528]. JAMA. 1996;275:693-698.
28 Virtamo J, Rapola JM, Ripatti S, et al. Effect of vitamin E and beta carotene on the incidence of primary nonfatal myocardial infarction and fatal coronary heart disease. Arch Intern Med. 1998;158:668-675.
29 Heart Protection Study Collaboration Group. MRC/BHF Heart Protection Study of antioxidant vitamin supplementation in 20,536 high‐risk individuals: a randomised placebo‐controlled trial. Lancet 2002 360 23 33
30 Klipstein‐Grobusch K, Geleijnse JM, J. H. den Breeijen JH, et al. Dietary antioxidants and risk of myocardial infarction in the elderly: The Rotterdam Study. Am J Clin Nutr. 1999;69:261-266.
31 Watkins ML, Erickson JD, Thun MJ, Mulinare J, Heath CW Jr. Multivitamin use and mortality in a large prospective study. Am J Epidemiol. 2000;152:149-162.
32 Knekt P, Reunanen A, Jarvinen R, Seppanen R, Heliovaara M, Aromma A. Antioxidant vitamin intake and coronary mortality in a longitudinal population study. Am J Epidemiol. 1994;139:1180-1189.
33 Age‐related Eye disease Study Research Group. A randomized, placebo‐controlled clinical trial of high‐dose supplementation with vitamins C and E and beta‐carotene for age‐related cataract and vision loss: AREDS Report No. 9. Arch Ophthalmol 2001 119 1439 1452
34 Waters DD, Alderman EL, Hsia J, et al. Effects of hormone replacement therapy and anioxidant vitamin supplements on coronary atherosclerosis in postmenopausal women. JAMA. 2002;288:2432-2440.
35 Giovannucci E, Stampfer MJ, Colditz GA, et al. Multivitamin use, folate, and colon cancer in women in the Nurses' Health Study. Ann Intern Med. 1998;129:517-524.
36 Rimm EB, Willett WC, Hu FB, et al. Folate and vitamin B6 from diet and supplements in relation to risk of coronary heart disease among women. JAMA. 1998;279:359-364.
37 Muntwyler J, Hennekens CH, Manson JE, Buring JE, Gaziano JM. Vitamin supplement use in a low‐risk population of U.S. male physicians and subsequent cardiovascular mortality. Arch Intern Med. 2002;162:1472-1476.
38 Taylor BV, Oudit GY, Evans M. Homocysteine, vitamins, and coronary artery disease: Comprehensive review of the literature. Can Fam Physician. 2000;46:2236-2245.
39 American Academy of Family Physicians. AAFP Clinical Recommendations. Available at: http://www.aafp.org/policy/camp/19.html. Accessed Mar 27, 2002.
40 Canadian Task Force on Preventive Health Care. Available at: http://www.ctfrpc.org/Whats New/reviews_in_progress.html. Accessed Mar 27, 2002.
41 American Cancer Society. Prevention and early detection: Nutrition for risk reduction. Available at: http://www.cancer.org/eprise/main/docroot/ped/ped_3?sitearea+PED&level=1. Accessed Mar 27, 2002.
42 American Heart Association. Vitamins and mineral supplements: AHA scientific position. Available at: http://216.185.112.5/presenter.jhtml?identifier=4788. Accessed Mar 27, 2002.