# Recommendations of Others

The American Academy of Family Physicians states that “the decision to provide special dietary intervention or nutrient supplementation must be on an individual basis using the family physician's best judgment based on evidence of benefit as well as lack of harmful effects. Megadoses of certain vitamins and minerals have been proven to be harmful.”^39^ The Canadian Task Force on Preventive Health Care is reviewing the role of vitamin E supplementation on the prevention of cardiovascular disease and cancer.^40^ The American Cancer Society recommends a well‐balanced diet and does not recommend the use of vitamin and mineral supplements as a preventive or therapeutic intervention.^41^ The American Heart Association Dietary Guidelines Revision 2000 recommends that vitamin and mineral supplements are not a substitute for a balanced and nutritious diet designed to emphasize the intake of fruits, vegetables, and grains.^42^