# Scientific Evidence

The USPSTF reviews^1^‐^3^ focused on the quality of the evidence regarding the effect of routine supplementation with certain vitamins on the primary prevention of cancer and cardiovascular disease. These reviews were undertaken because of the growing epidemiologic evidence that dietary factors may play a role in the etiology of these diseases.^7^‐^9^ The reviews focused on prospective trials of vitamin supplementation and observational studies of associations between the use of specific supplements and the risk for cancer or cardiovascular disease. The value of vitamins naturally occurring in food, the use of vitamin supplements for the prevention of other conditions (eg, neural tube defects), and the use of vitamin supplements for the secondary prevention of complications in patients with existing disease were outside the scope of these reviews.

## Vitamin A

No prospective trials have examined the effect of vitamin A supplements alone on the risk for cancer. Observational studies provide no evidence that such supplements prevent cancer in men. In women, observational studies have reported a statistically significant inverse association between use of vitamin A supplements and the risk for colon and breast cancer.^10,^ ^11^ Despite efforts to adjust for confounding variables, the observational, non‐random design of these studies makes it difficult to assess the extent to which the reduced cancer risk is attributable to vitamin A or to other characteristics of women who take vitamin A supplements. No evidence from prospective trials is available regarding the benefits of vitamin A alone in preventing cardiovascular disease. One good‐quality cohort study found no effect of vitamin A supplementation on reducing cardiovascular disease mortality.^12^

## Vitamin C

No primary prevention trial of the effect of vitamin C supplementation alone on cancer or cardiovascular disease has been reported. Observational studies have generally shown no significant associations between use of vitamin C supplements and the risk for cancers of the breast, prostate, colon, or lung.^12^‐^14^ The observational cohort studies examining the effects of vitamin C on cardiovascular disease have produced inconsistent results.^12,^ ^15,^ ^16^

## Vitamin E

Only a few trials have examined the effects of vitamin E on the primary prevention of cancer or cardiovascular disease. A randomized controlled trial (RCT) involving Finnish male smokers found that vitamin E supplementation was not protective against lung cancer but may have a beneficial impact on prostate cancer.^14^ Because prostate cancer was not a primary endpoint of the trial, and the trial suffered from other limitations, further evidence is needed to confirm this finding. Observational studies have shown no significant association between vitamin E supplement use and the risk for prostate, lung, or breast cancer.^2^ One study suggested that vitamin E protects against colon cancer, but the influence of confounding variables cannot be fully excluded.^17^ Among primary prevention trials, 2 good‐quality^14,^ ^18^ and 1 fair‐quality trial^19^ found no significant benefit of vitamin E supplementation on preventing cardiovascular disease.^20^ Only 1 of 7 trials of vitamin E supplementation for secondary prevention demonstrated a significant reduction in cardiac events.^1^ Some prospective cohort studies have suggested a significant benefit, but the results are mixed and the influence of confounding variables cannot be excluded.^1^

## Beta‐carotene

A consistent body of evidence from clinical trials suggests that beta‐carotene supplementation does not decrease the risk for lung, prostate, colon, breast, or non‐melanoma skin cancer.^14,^ ^21^‐^25^ Beta‐carotene supplements were associated with an increased risk for lung cancer among smokers, especially heavy smokers, in 2 RCTs.^14,^ ^25^ Results from 4 RCTs demonstrate no reduced risk for cardiovascular events or mortality after beta‐carotene supplementation.^14,^ ^21,^ ^22,^ ^26^‐^28^

## Antioxidant Vitamin Combinations

Studies of the effects of antioxidant vitamin combinations to prevent cancer have yielded mixed results. A recent RCT reported no significant effect of daily supplementation of a combination of antioxidants: vitamin E, vitamin C, and beta‐carotene.^29^ Some studies have suggested an adverse effect of antioxidant combinations on cancer, but the results may have been confounded by the inclusion of beta‐carotene.^2^ Some observational studies of antioxidant vitamin combinations have suggested a benefit in preventing cardiovascular disease^13^,^30,^ ^31^, but other studies, including well‐designed RCTs, have shown no benefit.^29,^ ^32,^ ^33^ One secondary prevention trial showed an increase in all‐cause mortality among women taking antioxidant supplements.^34^

## Multiple Vitamin Combinations

The incremental benefit of taking supplemental doses of folic acid and the B vitamins has been examined by comparing the outcomes of observational studies while controlling for the total intake of antioxidant vitamin supplements.35 In these analyses, folic acid supplementation was associated with significantly decreased risk for colon cancer, but the protective effect requires confirmation in prospective trials. There is conflicting evidence regarding the use of multivitamins and the risk for cardiovascular disease. Among cohort studies, 1 good‐quality study reported a significant reduction in coronary events,^36^ 2 good‐quality studies reported no significant effect on mortality,^16^,^37^ and 1 fair‐quality study reported an increase in all‐cause mortality in men.^31^ No trial has examined the effect of either folate or multivitamins on the primary prevention of cardiovascular disease, but such studies are currently underway.

## Potential Harms of Vitamin Supplementation

There are several known adverse effects caused by excessive doses of vitamins; for example, moderate doses of vitamin A supplements may reduce bone mineral density, and high doses may be hepatotoxic or teratogenic. A small but significant increase in lung cancer mortality observed in trials of smokers has been ascribed to beta‐carotene supplementation; adverse effects of beta‐carotene supplementation on non‐smokers have not been observed on other trials. The adverse effects of vitamin supplementation were not reported in most studies reviewed by the USPSTF. More studies are needed to better understand the harms of vitamin supplementation.