# Summary of Recommendations

• The U.S. Preventive Services Task Force (USPSTF) concludes that the evidence is insufficient to recommend for or against the use of supplements of vitamins A, C, or E; multivitamins with folic acid; or antioxidant combinations for the prevention of cancer or cardiovascular disease.

Rating: I recommendation (http://www.ahrq.gov/clinic/3rduspstf/ratings.htm#irec).

Rationale: The USPSTF found poor evidence to determine whether supplementation with these vitamins reduces the risk for cardiovascular disease or cancer. The available evidence from randomized trials is either inadequate or conflicting, and the influence of confounding variables on observed outcomes in observational studies cannot be determined. As a result, the USPSTF could not determine the balance of benefits and harms of routine use of supplements of vitamins A, C or E; multivitamins with folic acid; or antioxidant combinations for the prevention of cancer or cardiovascular disease.

• The USPSTF recommends against the use of beta‐carotene supplements, either alone or in combination, for the prevention of cancer or cardiovascular disease.

Rating: D recommendation (http://www.ahrq.gov/clinic/3rduspstf/ratings.htm#drec).

Rationale: The USPSTF found good evidence that beta‐carotene supplementation provides no benefit in the prevention of cancer or cardiovascular disease in middle‐aged and older adults. In 2 trials restricted to heavy smokers, beta‐carotene supplementation was associated with higher incidence of lung cancer and higher all‐cause mortality. The USPSTF concludes that beta‐carotene supplements are unlikely to provide important benefits and might cause harm in some groups.