# References

1. U.S. Preventive Services Task Force. Screening for Skin Cancer. Guide to Clinical Preventive Services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996:141‐52.
2 Helfand M, Krages K. Counseling to Prevent Skin Cancer. Summary of the Evidence for the U.S. Preventive Services Task Force. Rockville, MD: Department of Health and Human Services, Agency for Healthcare Research and Quality. Available at http://www.ahrq.gov/clinic/3rduspstf/skcacoun/skcounsum.htm.
3 Ries LA, Kosary CL, Hankey BF, Miller BA, Edwards BK, eds. SEER Cancer Statistics Review, 1973‐95. Bethesda: National Cancer Institute; 1998.
4 Nelemans PJ, Rampen FH, Ruiter DJ, Verbeek AL. An addition to the controversy on sunlight exposure and melanoma risk: a meta‐analytical approach. J Clin Epidemiol. 1995;48(11):1331-42. [pmid: 7490596].
5 Elwood M, Jopson J. Melanoma and sun exposure: an overview of published studies. Int J Cancer. 1997;73(2):198-203. [pmid: 9335442].
6 Walter S, King W, Marrett L. Association of cutaneous malignant melanoma with intermittant exposure to ultraviolet radiation: results of a case‐control study in Ontario, Canada. Int J Epidemiol. 1999;28(3):418-27. [pmid: 10405843].
7 Holly EA, Aston DA, Cress RD, Ahn DK, Kristiansen JJ. Cutaneous melanoma in women. I. Exposure to sunlight, ability to tan, and other risk factors related to ultraviolet light. Am J Epidemiol. 1995;141(10):923-33. [pmid: 7741122].
8 Swerdlow AJ, Weinstock MA. Do tanning lamps cause melanoma? An epidemiologic assessment. J Am Acad Dermatol. 1998;38(1):89-98. [pmid: 9448211].
9 Green A, Williams G, Neale R, et al. Daily sunscreen application and beta‐carotene supplementation in prevention of basal‐cell and squamous‐cell carcinomas of the skin: a randomised controlled trial. Lancet. 1999;354(9180):723-9. [pmid: 10475183].
10 Thompson SC, Jolley D, Marks R. Reduction of solar keratoses by regular sunscreen use. N Engl J Med. 1993;329(16):1147-51. [pmid: 8377777].
11 Autier P, Dore JF, Schifflers E, et al. Melanoma and use of sunscreens: an EORTC case‐control study in Germany, Belgium and France. The EORTC Melanoma Cooperative Group. Int J Cancer. 1995;61(6):749-55. [pmid: 7790106].
12 Autier P, Dore JF, Cattaruzza MS, et al. Sunscreen use, wearing clothes, and number of nevi in 6‐ to 7‐year‐old European children. European Organization for Research and Treatment of Cancer Melanoma Cooperative Group. J Natl Cancer Inst. 1998;90(24):1873-80. [pmid: 9862624].
13 Westerdahl J, Olsson H, Masback A, Ingvar C, Jonsson N. Is the use of sunscreens a risk factor for malignant melanoma?. Melanoma Res. 1995;5(1):59-65. [pmid: 7734957].
14 Huncharek M, Kupelnick B. Use of topical sunscreens and the risk of malignant melanoma: a meta‐analysis of 9067 patients from 11 case‐control studies. Am J Public Health. 2002;92(7):1173-77. [pmid: 12084704]. [pmcid: 1447210].
15 Berwick M, Begg CB, Fine JA, Roush GC, Barnhill RL. Screening for cutaneous melanoma by skin self‐examination [see comments]. J Natl Cancer Inst. 1996;88(1):17-23. [pmid: 8847720].
16 Easton A, Price J, Boehm K, Telljohann S. Sun protection counseling by pediatricians. Arch Pediatr Adolesc Med. 1997;151(11):1133-38. [pmid: 9369875].
17 Dietrich AJ, Olson AL, Sox CH, Tosteson TD, Grant‐Petersson J. Persistent increase in children's sun protection in a randomized controlled community trial. Prev Med. 2000;31(5):569-74. [pmid: 11071838].
18 Autier P, Dore JF, Negrier S, et al. Sunscreen use and duration of sun exposure: a double‐blind, randomized trial. J Natl Cancer Inst 1999;91(15):1304‐9.
19. American Cancer Society (ACS). Cancer Prevention & Early Detection Facts & Figures 2003. Atlanta, Georgia. Available at: http://www.cancer.org/docroot/STT/content/STT_1x_Cancer_Prevention__Early_Detection_Facts__Figures_2003.asp or at http://www.cancer.org/downloads/STT/CPED2003PWSecured.pdf. Accessed March 13, 2003.
20. Lim HW, Cooper K. The health impact of solar radiation and prevention strategies: report of the Environmental Council, American Academy of Dermatology. J Am Acad Dermotol. 1999;41(1):81-99.
21. Ultraviolet light: a hazard to children (RE9913). American Academy of Pediatrics, Committee on Environmental Health. Pediatrics. 1999;104:328-33. [pmid: 10429020].
22 American College of Obstetricians and Gynecologists. Primary and preventive care: periodic assessments. ACOG Committee Opinion 246. Washington, DC: ACOG, 2000.
23. Diagnosis and treatment of early melanoma. NIH Consensus Development Conference, January 27‐29, 1992. Vol 10, Number 1.
24. "Sun‐Safe Guidelines." American Academy of Family Physicians. Available at http://www.aafp.org/afp/20000715/375ph.html. Accessed March 12, 2003.
25 Ferrini RL, Perlman M, Hill L. Skin protection from ultraviolet light exposure: American College of Preventive Medicine Practice Policy Statement. Available at http://www.acpm.org/skinprot.htm. Accessed March 12, 2003.
26 International Agency for Research on Cancer (IARC). Handbooks of Cancer Prevention: Sunscreens. 2001; Vol 5. IARC Press: Lyon, France.
27 Centers for Disease Control and Prevention. Preventing Skin Cancer: Findings of the Task Force on Community Preventive Services on reducing exposure to ultraviolet light. MMWR 2003;52 (No. RR‐15): 13‐17.