# Recommendations of Others

The American Cancer Society,^19^ the American Academy of Dermatology,^20^ the American Academy of Pediatrics,^21^ the American College of Obstetricians and Gynecologists,^22^ and a National Institutes of Health consensus panel^23^ all recommend patient education concerning sun avoidance and sunscreen use. The American Academy of Family Physicians recommends sun protection for all with increased sun exposure.^24^ The American College of Preventive Medicine (ACPM) concluded that sun‐protective measures (e.g., clothing, hats, opaque sunscreens) are probably effective in reducing skin cancer but that the evidence does not support discussion of sunscreen and sun protection with every patient. ACPM concluded that evidence is insufficient to advise patients that chemical sunscreens protect against malignant melanoma and that their use may actually lead to increased risk.^25^ Recently, the International Agency for Research on Cancer (IARC), part of the World Health Organization, qualified their recommendation for sunscreen use in ways that address the importance of learning more about potential harms of counseling for sunscreen use as follows:

"Sunscreens probably prevent squamous‐cell carcinoma of the skin when used mainly during unintentional sun exposure. No conclusion can be drawn about the cancer‐preventive activity of topical use of sunscreens against basal‐cell carcinoma and cutaneous melanoma. Use of sunscreens can extend the duration of intentional sun exposure, such as sunbathing. Such an extension may increase the risk for cutaneous melanoma."^26^

The Task Force on Community Preventive Services found insufficient evidence to determine the effectiveness of a range of population‐based interventions to reduce unprotected ultraviolet light exposure and recommended additional research on educational and policy approaches, media campaigns, and both health care setting and community‐based interventions. ^27^