# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 McTigue K. Screening and interventions for overweight and obesity in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;139(11):933-49. [pmid: 14644897].
3 McTigue K, Harris R, Hemphill MB, et al. Screening and Interventions for Obesity in Adults. Systematic Evidence Review No. 21 (Prepared by the Research Triangle Institute‐University of North Carolina Evidence‐based Practice Center under Contract 290‐97‐0011). Rockville, MD: Agency for Healthcare Reseach and Quality. December 2003. Available on the AHRQ Web site at www.ahrq.gov/clinic/serfiles.htm.
4 Centers for Disease Control and Prevention: Department of Health and Human Services. Health, United States, 2000.
5 National Health and Nutrition Examination Survey (NHANES). CDC, 1999.
6 Roe DA, Eickwort KR. Relationships between obesity and associated health factors with unemployment among low income women. J Am Med Womens Assoc 1976;31(5):193‐4, 198‐9, 203‐4.
7 Wolf AM, Colditz GA. Current estimates of the economic cost of obesity in the United States. Obes Res. 1998;6(2):97-106. [pmid: 9545015].
8 Gray DS, Fujioka K. Use of relative weight and body mass index for the determination of adiposity. J Clin Epidemiol. 1991;44(6):545-50. [pmid: 2037859].
9 Deurenberg P, Weststrate JA, Seidell JC. Body mass index as a measure of body fatness: age‐ and sex‐specific prediction formulas. Br J Nutr. 1991;65(2):105-14. [pmid: 2043597].
10 Deurenberg P, van der Kooy K, Hulshof T, Evers P. Body mass index as a measure of body fatness in the elderly. Eur J Clin Nutr. 1989;43(4):231-6. [pmid: 2661215].
11 Shaper AG, Wannamethee SG, Walker M. Body weight: implications for the prevention of coronary heart disease, stroke, and diabetes mellitus in a cohort study of middle aged men. BMJ. 1997;314(7090):1311-7. [pmid: 9158466]. [pmcid: 2126570].
12 Huang Z, Willett WC, Manson JE, et al. Body weight, weight change, and risk for hypertension in women. Ann Intern Med. 1998;128(2):81-8. [pmid: 9441586].
13 Durazo‐Arvizu RA, McGee DL, Cooper RS, Liao Y, Luke A. Mortality and optimal body mass index in a sample of the US population. Am J Epidemiol. 1998;147(8):739-49. [pmid: 9554415].
14 Calle EE, Thun MJ, Petrelli JM, Rodriguez C, Heath CWJ. Body‐mass index and mortality in a prospective cohort of U.S. adults. N Engl J Med. 1999;341(15):1097-105. [pmid: 10511607].
15 Rosengren A, Wedel H, Wilhelmsen L. Body weight and weight gain during adult life in men in relation to coronary heart disease and mortality. A prospective population study. Eur Heart J. 1999;20(4):269-77. [pmid: 10099921].
16 Kim KS, Owen WL, Williams D, Adams‐Campbell LL. A comparison between BMI and Conicity index on predicting coronary heart disease: the Framingham Heart Study. Ann Epidemiol. 2000;10(7):424-31. [pmid: 11018345].
17 Willett WC, Manson JE, Stampfer MJ, et al. Weight, weight change, and coronary heart disease in women. Risk within the 'normal' weight range. JAMA. 1995;273(6):461-5. [pmid: 7654270].
18 Colditz GA, Willett WC, Rotnitzky A, Manson JE. Weight gain as a risk factor for clinical diabetes mellitus in women. Ann Intern Med. 1995;122(7):481-6. [pmid: 7872581].
19 Wannamethee SG, Shaper AG, Walker M, Ebrahim S. Lifestyle and 15‐year survival free of heart attack, stroke, and diabetes in middle‐aged British men. Arch Intern Med. 1998;158(22):2433-40. [pmid: 9855381].
20 Baik I, Ascherio A, Rimm EB, et al. Adiposity and mortality in men. Am J Epidemiol. 2000;152(3):264-71. [pmid: 10933273].
21 Folsom AR, Kushi LH, Anderson KE, et al. Associations of general and abdominal obesity with multiple health outcomes in older women: the Iowa Women's Health Study. Arch Intern Med. 2000;160(14):2117-28. [pmid: 10904454].
22 Galuska DA, Will JC, Serdula MK, Ford ES. Are health care professionals advising obese patients to lose weight?. JAMA. 1999;282(16):1576-8. [pmid: 10546698].
23 Whitlock E, Orleans C, Pender N, Allan J. Evaluating primary care behavioral counseling interventions: an evidence‐based approach. Am J Prev Med. 2002;22(4):267-84. [pmid: 11988383].
24 Douketis JD, Feightner JW, Attia J, Feldman WF. Periodic health examination, 1999 update: 1. Detection, prevention and treatment of obesity. Canadian Task Force on Preventive Health Care. CMAJ 1999;160(4):513‐25. Available at http://www.cmaj.ca/cgi/reprint/160/4/513.pdf.
25 NHS Centre for Reviews and Dissemination, University of York. The prevention and treatment of obesity Eff Health Care 1997 3 2 1 12
26 NHLBI Obesity Education Initiative. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: the Evidence Report. NIH Publication No. 98‐4083. Bethesda, MD: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Heart, Lung, and Blood Institute; 1998.
27 Stevens J. Obesity and mortality in African‐Americans. Nutr Rev. 2000;58(11):346-53. [pmid: 11140906].
28 Kuller LH, Simkin‐Silverman LR, Wing RR, Meilahn EN, Ives DG. Women's Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32-7. [pmid: 11136682].
29 Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343-50. [pmid: 11333990].
30 Diabetes Prevention Program Research Group. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin N Engl J Med 2002 346 6 393 403 11832527 1370926
31 Arterburn D, Noel PH. Effects of drug treatment for obesity in adults. Clin Evid 2001:412‐9.
32 Wadden TA, Berkowitz RI, Sarwer DB, Prus‐Wisniewski R, Steinberg C. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001;161(2):218-27. [pmid: 11176735].
33 Must A, Spadano J, Coakley EH, Field AE, Colditz G, Dietz WH. The disease burden associated with overweight and obesity. JAMA. 1999;282(16):1523-9. [pmid: 10546691].
34 Pories WJ, Swanson MS, MacDonald KG, et al. Who would have thought it? An operation proves to be the most effective therapy for adult‐onset diabetes mellitus. Ann Surg 1995;222(3):339‐50; discussion 350‐2.
35 Sjostrom CD, Lissner L, Wedel H, Sjostrom L. Reduction in incidence of diabetes, hypertension and lipid disturbances after intentional weight loss induced by bariatric surgery: the SOS Intervention Study. Obes Res. 1999;7(5):477-84. [pmid: 10509605].
36 Brolin RE, Bradley LJ, Wilson AC, Cody RP. Lipid risk profile and weight stability after gastric restrictive operations for morbid obesity. J Gastrointest Surg. 2000;4(5):464-9. [pmid: 11077320].
37 Choban P, Atkinson R, Moore BJ. (Shape up America and the American Obesity Association.) Guidance for treatment of adult obesity, 1996: 1996‐1998.
38 Sbrocco T, Nedegaard RC, Stone JM, Lewis EL. Behavioral choice treatment promotes continuing weight loss: preliminary results of a cognitive‐behavioral decision‐based treatment for obesity. J Consult Clin Psychol. 1999;67(2):260-6. [pmid: 10224737].
39 National Task Force on the Prevention and Treatment of Obesity. Overweight, complications obesity and health risk Arch Intern Med 2000 160 898 904 10761953
40 American Academy of Family Physicians. Periodic Health Examinations. Recommend: General Population. Revision 5.3, August 2002. Available at http://www.aafp.org/x10598.xml.
41 Nawaz H, Katz D. American College of Preventive Medicine Medical Practice Policy Statement: Weight Management Counseling for Overweight Adults. Am J Prev Med 2001;21:73‐8. Available at http://www.acpm.org/polstmt_weight.pdf.
42 Franz MJ, Bantle JP, Beebe CA, et al. Evidence based nutrition principles and recommendations for the treatment and prevention of diabetes and related complications. Diabetes Care 2002;25:148‐98. Available at care.diabetesjournals.org/cgi/content/full/25/1/148.