# Recommendations of Others

In 1998, the Centers for Disease Control and Prevention (CDC) concluded that testing for BV "may be conducted early in the second trimester for asymptomatic patients who are at high risk for preterm labor (e.g., those who have a history of previous preterm delivery). Current evidence does not support universal testing for BV" (3). Updated recommendations from CDC are expected in 2001. A similar conclusion was reached in 1998 by the American College of Obstetricians and Gynecologists (4). A systematic review of randomized controlled trials of BV treatment, completed in 1998 for the Cochrane Collaboration, concluded that evidence did not support screening all pregnant women but that there was some evidence of benefit for women with a history of a previous preterm delivery (5).