# Scientific Evidence

## Epidemiology and Clinical Consequences

Breast cancer is the most common non-skin malignancy among women in the United States and second only to lung cancer as a cause of cancer-related death. In 2001, an estimated 192,200 new cases of breast cancer were diagnosed in American women, and 40,200 women died of the disease.^4^ The risk of developing breast cancer increases with age beginning in the fourth decade of life. The probability of developing invasive breast cancer over the next 10 years is 0.4 percent for women aged 30-39, 1.5 percent for women aged 40-49, 2.8 percent for women aged 50-59, and 3.6 percent for women aged 60-69.^4^ Individual factors other than age that increase the risk for developing breast cancer include family history or a personal history of breast cancer, biopsy-confirmed atypical hyperplasia, and having a first child after age 30.^5^

## Accuracy and Reliability of Screening Tests

The USPSTF examined the test characteristics of mammography, CBE, and BSE. Precise estimates of sensitivity and specificity of screening are made more difficult by the varied criterion standards in available studies. Estimating the predictive value of positive and negative tests is also difficult because studies have been conducted on populations with a widely varying prevalence of breast cancer.

### Mammography

Estimates of the sensitivity of mammography vary with the methods used to calculate it.^2^ In a good quality systematic review, the first round of mammography detected 77 percent to 95 percent of cancers diagnosed over the following year, but only 56 percent to 86 percent of cancers diagnosed over the next 2 years.^6^ Sensitivity is lower among women who are younger than 50 (51 percent to 83 percent), have denser breasts, or are taking hormone replacement therapy.^3^

In screening trials, the false-positive rate of the initial round of mammography was 3 percent to 6 percent (ie, specificity 94 percent to 97 percent).^3^ Specificity is increased with a shorter screening interval and the availability of prior mammograms.^3^ In a large study in a health maintenance organization, the rate of false-positive mammograms (those requiring some additional followup) was higher in women aged 40-59 (7 percent to 8 percent) than in women aged 60-79 (4 percent to 5 percent).^7^

The probability that an abnormal mammogram is due to cancer increases with age. A large study in Northern California estimated positive predictive values for abnormal mammograms at 2 percent to 4 percent among women aged 40-49, 5 percent to 9 percent among women aged 50-59, and 7 percent to 19 percent among women aged 60 and older.^3,8^ Positive predictive values were also higher among women with a family history of breast cancer in two studies.^3^

### Clinical breast examination

In a recent good quality review of data from clinical trials, the sensitivity of CBE ranged from 40 percent to 69 percent, specificity from 86 percent to 99 percent, and positive predictive value from 4 percent to 50 percent, using mammography and interval cancer as the criterion standard.^9^ In a large community study, only 4 percent of women with an abnormal CBE were subsequently diagnosed with cancer.^10^

### Breast self-examination

The accuracy of BSE is largely unknown. Available evidence shows sensitivity ranging from 26 percent to 41 percent compared with CBE and mammography.^3^ Specificity of BSE is largely unknown.

## Effectiveness of Early Detection

The USPSTF reviewed 8 randomized controlled trials (RCTs) of mammography (4 of mammography alone and 4 of mammography plus CBE) that have reported results with 11-20 years of followup.^8-15^

The USPSTF found important methodological limitations in each trial, but rated only one trial as "poor" based on established criteria used by the USPSTF to evaluate the quality of evidence for screening tests. The most serious problems concerned the assembly and maintenance of comparable groups, methods for ascertaining outcomes, and generalizability to routine practice. The USPSTF concluded that the flaws were problematic but unlikely to negate the reasonably consistent and significant mortality reductions observed in these trials.

Imperfections in the mammography trials have been recognized and discussed in the literature and by the original investigators for many years. Recently, a 2001 Cochrane Collaboration review of the same trials concluded that six of the eight trials were "flawed" or of "poor quality" and that the pooled results from the remaining two better trials did not support a benefit from mammography.

Although the USPSTF was concerned about many (but not all) of the flaws identified in this review, it did not consider the presence of flaws sufficient reason in itself for rejecting trial results. Instead, it examined whether observed mortality reductions in the trials were likely to be explained by the biases potentially introduced by such flaws. Studies rated to be of "fair" quality by the USPSTF contained flaws that were considered unlikely to account for observed benefits (or lack of benefits).

The trials reported mortality reductions ranging from no significant effect (the Canadian trial) to a 32 percent reduction in breast cancer mortality. The meta-analysis performed for the USPSTF on the most current published data found that the pooled effect size of the combined trials was sizable and statistically significant: the summary relative risk (RR) of breast cancer death among women randomized to screening in seven trials that included women older than 50 was 0.77 (95 percent CI, 0.67-0.89). Eliminating one trial considered to be of poor quality and one trial that lacked a usual care control group did not change the results (RR = 0.75, 95 percent CI 0.63-0.89). Similar results were observed in the four trials of mammography alone: RR= 0.74 (95 percent CI 0.59-0.93).

Earlier subgroup analyses from mammography trials raised questions about whether screening is effective in women younger than 50. Seven trials enrolled women aged 40-49. Six of these were rated by the USPSTF to be of at least "fair" quality, but only one of these was designed to specifically address the benefits of screening in this age group: it reported no reduction in breast cancer mortality with annual mammography and CBE.^17^

Of the remaining five fair-quality trials that included women younger than 50, two trials have now reported significant mortality reductions with screening in this age group^12,14^, two have reported non-significant mortality reductions^11,15^, and 1 found no benefit.^13^

In a meta-analysis performed for the USPSTF pooling results for women aged 40-49 in these six trials, the relative risk of breast cancer mortality was 0.83 (95 percent CI 0.64-1.04) among screened women; inclusion of the seventh, poor-quality study did not change results.^2^ These results are similar to prior meta-analyses based on older data.

Because these data represent a subgroup analysis of trials not designed to test the benefits of beginning screening at a specific age, questions remain about the additional benefits of beginning screening before age 50. On average, the time until mortality benefits begin to be observed in these trials is longer in women younger than 50 than in older women (8 years vs 3 to 4 years) and some of the observed benefits could be due to screening after age 50.^3,22^ Analyses of individual studies suggest that at least some of the mortality reduction is due to early detection of tumors before age 50, but definitive estimates of the proportion of benefits due to early screening cannot be made.^3,23^

### Clinical Breast Examination

No study has compared CBE to no screening. The reductions in breast cancer mortality in studies using mammography alone are comparable to those using mammography plus CBE.^3,23^

### Breast Self-Examination

The role of BSE in reducing breast cancer mortality has been evaluated in one Chinese^24^ and one Russian^25^ RCT and one non-randomized controlled trial of BSE education in the United Kingdom.^26^ None of the three trials has demonstrated a reduction in breast cancer mortality or significant improvements in the number or stage of cancers detected, with followup ranging from 5 to 14 years; followup is continuing in one trial that observed a slight non-significant reduction in mortality in the BSE group at 9 years.^25^ In a good-quality nested case-control analysis from a Canadian screening study, the overall practice of BSE was not associated with a reduction in mortality.^27^

Although none of these studies provides support for BSE, the USPSTF concluded that these studies did not exclude a possible benefit, due to their limited duration of followup and questions about whether results from other countries are generalizable to women in North America.

## When To Stop Screening

Although there are no trial data directly evaluating screening in women older than 74, two RCTs suggest benefits among women enrolled in screening trials up to ages 70 and 74.^14,15^ Because risk of breast cancer is high after age 70, the benefits of mammography could be important. However, this is offset by the fact that some older women (especially the very old and those with comorbid illness) will die from other causes before they observe any benefits from early detection.

## Screening Interval

In clinical trials, mortality reductions occurred in programs with screening intervals ranging from 12-33 months, with no clear difference due to interval.^13-21^ Data suggest that breast cancer grows more rapidly in women younger than 50, and the sensitivity of mammography is lower in this age group; thus, shorter screening intervals have been advocated for women aged 40-49. Among the trials showing or suggesting a benefit of screening in women younger than 50, screening intervals that ranged from 12-33 months appeared to achieve comparable results, providing no direct evidence of incremental benefits over annual screening.^13,14,16-18^

## Potential Harms of Screening

Similar to other cancer screening tests, the large majority (80 percent to 90 percent) of abnormal screening mammograms or CBEs are false-positives.^3^ These may require followup testing or invasive procedures such as breast biopsy to resolve the diagnosis, and can result in anxiety, inconvenience, discomfort, and additional medical expenses.^3^

In one large community study, 6.5 percent of screening mammograms required some additional followup and, over a 10-year period, 23 percent of all women had experienced at least one abnormal mammogram.^7^ The cumulative risk of a false-positive result after 10 mammograms was estimated to be 49 percent.^7^ The proportion of false-positive results that lead to biopsy varies substantially in different settings.^28^ In screening trials, 1 percent to 6 percent of all women screened underwent biopsy, and the proportion of biopsies that revealed cancer ranged from 12 percent to 78 percent.^28^ In two RCTs, BSE education resulted in a nearly two-fold increase in false-positive results, physician visits, and biopsies for benign disease.^24,25^

The consequences of false-positive mammograms are uncertain. Most, but not all, studies report increased anxiety from an abnormal mammogram.^2^ At the same time, some studies report that women in the United States may be willing to accept a relatively high number of false-positive results in the population in return for the benefits of mammography.^2,29^ Studies do not indicate that false-positive results diminish adherence to subsequent screening.^3^

False-negatives also occur with mammograms and CBE. Although false-negative results might provide false reassurance, the USPSTF found no data indicating these led to further delays in diagnosis.^3^

Some experts view the over-diagnosis and treatment of ductal carcinoma in situ (DCIS) as a potential adverse consequence of mammography. Although the natural history of DCIS is variable, many women in the United States are treated aggressively with mastectomy or lumpectomy and radiation.^2^ Given the dramatic increase in the incidence of DCIS in the past two decades (750 percent) and autopsy series suggesting that there is a significant pool of DCIS among women who die of other causes^3^, screening may be increasing the number of women undergoing treatment for lesions that might not pose a threat to their health.

A final potential concern about mammography is radiation-induced breast cancer, but there are few data to directly assess this risk. A 1997 review, using risk estimates provided by the Biological Effects of Ionizing Radiation report of the National Academy of Sciences, estimated that annual mammography of 100,000 women for 10 consecutive years beginning at age 40 would result in up to 8 radiation-induced breast cancer deaths.^30^