# Recommendations of Others

The Canadian Task Force on Preventive Health Care finds insufficient evidence to recommend for or against BMI measurement in the periodic health examination of the general population and found insufficient evidence to recommend for or against community‐based obesity prevention programs.^24^ The American Academy of Family Physicians^40^ and the American College of Obstetricians and Gynecologists recommend periodic measurements of height and weight. NIH has a 2‐step guideline of assessment and treatment management of overweight and obese individuals.^26^ The American College of Preventive Medicine recommends periodic BMI measurement of all adults and diet and exercise counseling of all adults (irrespective of BMI) and endorses NIH management guidelines.^41^ The American Diabetes Association has published a position statement that recommends the use of intensive lifestyle modification programs along with standard weight loss strategies for long‐term weight loss and maintenance.^42^