# Discussion

Epidemiologic data and some intervention trials support the hypothesis that screening for and treating BV may reduce the risk of preterm delivery among some women. Studies published to date do not suggest any benefit of treating BV among asymptomatic, average-risk women, but additional studies of earlier intervention with different drug regimens are being conducted in these populations. At present, however, the lack of demonstrated benefit and possibility of adverse effects of treatment in women without BV suggest that routine screening of average-risk women should be discouraged outside of research protocols. For pregnant women with prior preterm delivery, the inconsistent results of well-done studies prevent a clear recommendation for or against screening. Reasons for the conflicting results are not clear but may involve differences in other risk factors for preterm delivery among enrolled women or differences in drug regimens and timing of therapy. Further studies are needed, using diagnostic criteria and treatment protocols that are representative of community practice.