# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Ammerman A, Pignone M, Fernandez L, et al. Counseling to Promote a Healthy Diet. Systematic Evidence Review No. 18 (Prepared by Research Triangle Institute‐University of North Carolina Evidence‐Based Practice Center under Contract No. 290‐97‐011). Rockville, MD: Agency for Healthcare Research and Quality. April 2002. Available on the AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm.
3 McTigue K, Harris R, Hemphill MB, Bunton A. Screening and Interventions for Overweight and Obesity in Adults. Systematic Evidence Review. Rockville, MD: Agency for Healthcare Research and Quality (in press).
4 Pignone MP, Phillips CJ, Lannon CM, et al. Screening for Lipid Disorders. Systematic Evidence Review No. 4 (Prepared by Research Triangle Institute‐University of North Carolina Evidence‐Based Practice Center under Contract No. 290‐97‐011). Rockville, MD: Agency for Healthcare Research and Quality. April 2001. Available on the AHRQ Web site at: http://www.ahrq.gov/clinic.serfiles.htm
5 Obarzanek E, Hunsberger SA, Van Horn L, et al. Safety of a fat‐reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics. 1997;100(1):51-59. [pmid: 9200359].
6 Obarzanek E, Kimm SY, Barton BA, et al. Long‐term safety and efficacy of a cholesterol‐lowering diet in children with elevated low‐density lipoprotein cholesterol: seven‐year results of the Dietary Intervention Study in Children (DISC). Pediatrics. 2001;107(2):256-264. [pmid: 11158455].
7 Calfas KJ, Zabinski MF, Rupp J. Practical nutrition assessment in primary care settings: a review. Am J Prev Med. 2000;18(4):289-299. [pmid: 10788731].
8 Rockett HR, Colditz GA. Assessing diets of children and adolescents. Am J Clin Nutr. 1997;65(4):1116-1122.
9 Beresford SA, Farmer EM, Feingold L, Graves KL, Sumner SK, Baker RM. Evaluation of a self‐help dietary intervention in a primary care setting. Am J Public Health. 1992;82(1):79-84. [pmid: 1311152]. [pmcid: 1694422].
10 Coates RJ, Bowen DJ, Kristal AR, et al. The Women's Health Trial Feasibility Study in Minority Populations: changes in dietary intakes. Am J Epidemiol. 1999;149(12):1104-1112. [pmid: 10369504].
11 Kristal AR, Curry SJ, Shattuck AL, Feng Z, Li S. A randomized trial of a tailored, self‐help dietary intervention: the Puget Sound Eating Patterns study. Prev Med. 2000;31(4):380-389. [pmid: 11006063].
12 Little P, Barnett J, Margetts B, et al. The validity of dietary assessment in general practice. J Epidemiol Commun Health. 1999;53(3):165-172.
13 Whitlock EP, Orleans CT, Pender N, Allan J. Evaluating primary care behavioral counseling interventions: an evidence‐based approach. Am J Prev Med. 2002;22(4):267-284. [pmid: 11988383].
14 Maskarinec G, Chan CL, Meng L, Franke AA, Cooney RV. Exploring the feasibility and effects of a high‐fruit and ‐vegetable diet in healthy women. Cancer Epidemiol Biomarkers Prev. 1999;8(10):919-924. [pmid: 10548322].
15 Beresford SA, Curry SJ, Kristal AR, Lazovich D, Feng Z, Wagner EH. A dietary intervention in primary care practice: the Eating Patterns Study. Am J Public Health. 1997;87(4):610-616. [pmid: 9146440]. [pmcid: 1380841].
16 Ockene IS, Hebert JR, Ockene JK, et al. Effect of physician‐delivered nutrition counseling training and an office‐support program on saturated fat intake, weight, and serum lipid measurements in a hyperlipidemic population: Worcester Area Trial for Counseling in Hyperlipidemia (WATCH). Arch Int Med. 1999;159(7):725-731. [pmid: 10218753].
17 Ockene IS, Hebert JR, Ockene JK, Merriam PA, Hurley TG, Saperia GM. Effect of training and a structured office practice on physician‐delivered nutrition counseling: the Worcester‐Area Trial for Counseling in Hyperlipidemia (WATCH). Am J Prev Med. 1996;12(4):252-258. [pmid: 8874688].
18 U.S. Department of Health and Human Services. Nutrition and Your Health: Dietary Guidelines for Americans, Fifth Edition (2000). Available at http://www.health.gov/dietaryguidelines/. Accessed November 15, 2002.
19 U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. 2nd ed. Washington, DC: U.S. Government Printing Office; 2000. Available online at: http://www.health.gov/healthypeople/.
20 Glasgow RE, Eakin E. G., Fisher EB, Bacak SJ, Brownson RC. Physician advice and support for physical activity: results from a national survey. Am J Prev Med. 2001;21(3):189-196. [pmid: 11567839].
21 Kreuter MW, Chheda SG, Bull FC. How does physician advice influence patient behaviours?. Arch Fam Med. 2000;9:426-433. [pmid: 10810947].
22 Harris R, Helfand M, Woolf S, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(suppl 3):21-35. [pmid: 12174806].
23. Knutsen SF, Knutsen R. The Tromso Survey: the Family Intervention study—the effect of intervention on some coronary risk factors and dietary habits, a 6‐year followup. Prev Med. 1991;20(2):197-212. [pmid: 2057468].
24 Lindholm LH, Ekbom T, Dash C, Eriksson M, Tibblin G, Schersten B. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. 1995;310(6987):1105-1109. [pmid: 7742677]. [pmcid: 2549500].
25 Neaton JD, Broste S, Cohen L, Fishman EL, Kjelsberg MO, Schoenberger J. The multiple risk factor intervention trial (MRFIT). VII. A comparison of risk factor changes between the two study groups. Prev Med. 1981;10(4):519-543. [pmid: 7027241].
26 Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S. Behavioural counselling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial. BMJ 1999;319(7215):943‐947; discussion 947‐948.
27 Campbell MK, DeVellis BM, Strecher VJ, Ammerman AS, DeVellis RF, Sandler RS. Improving dietary behavior: the effectiveness of tailored messages in primary care settings. Am J Public Health. 1994;84(5):783-787. [pmid: 8179049]. [pmcid: 1615043].
28 Delichatsios HK, Hunt MK, Lobb R, Emmons K, Gillman MW. EatSmart: efficacy of a multifaceted preventive nutrition intervention in clinical practice. Prev Med. 2001;33(2 Pt 1):91-98. [pmid: 11716669].
29 Delichatsios HK, Friedman RH, Glanz K, et al. Randomized trial of a 'talking computer' to improve adults' eating habits. Am J Health Promot. 2001;15(4):215-224. [pmid: 11349340].
30 Henderson MM, Kushi LH, Thompson DJ, et al. Feasibility of a randomized trial of a low‐fat diet for the prevention of breast cancer: dietary compliance in the Women's Health Trial Vanguard Study. Prev Med. 1990;19(2):115-133. [pmid: 2193306].
31 Insull WJ, Henderson MM, Prentice RL, et al. Results of a randomized feasibility study of a low‐fat diet. Arch Intern Med. 1990;150(2):421-427. [pmid: 2405805].
32 Keyserling TC, Ammerman AS, Davis CE, Mok MC, Garrett J, Simpson RJ. A randomized controlled trial of a physician‐directed treatment program for low‐income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6(2):135-145. [pmid: 9075448].
33 Mojonnier ML, Hall Y, Berkson DM, et al. Experience in changing food habits of hyperlipidemic men and women. J Am Diet Assoc. 1980;77(2):140-148. [pmid: 7400495].
34 Roderick P, Ruddock V, Hunt P, Miller G. A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet‐related coronary heart disease risk. Br J Gen Pract. 1997;47(414):7-12. [pmid: 9115804]. [pmcid: 1312885].
35 Simkin‐Silverman LR, Wing RR. Management of obesity in primary care. Obesity Research. 1997;5(6):603-612. [pmid: 9449146].
36 Lutz SF, Ammerman AS, Atwood JR, Campbell MK, DeVellis RF, Rosamond WD. Innovative newsletter interventions improve fruit and vegetable consumption in healthy adults. J Am Diet Assoc. 1999;99(6):705-709. [pmid: 10361533].
37 Siero FW, Broer J, Bemelmans WJ, Meyboom‐de Jong BM. Impact of group nutrition education and surplus value of Prochaska‐ based stage‐matched information on health‐related cognitions and on Mediterranean nutrition behavior. Health Educ Res. 2000;15(5):635-647. [pmid: 11184222].
38 Baron JA, Gleason R, Crowe B, Mann JI. Preliminary trial of the effect of general practice based nutritional advice. Br J Gen Pract. 1990;40(333):137-141. [pmid: 2115348]. [pmcid: 1371239].
39 Ascherio A, Hennekens C, Willett WC, et al. Prospective study of nutritional factors, blood pressure, and hypertension among US women. Hypertension. 1996;27(5):1065-1072. [pmid: 8621198].
40 Bazzano LA, He J, Ogden LG, et al. Legume consumption and risk of coronary heart disease in US men and women: NHANES I Epidemiologic Followup Study. Arch Intern Med. 2001;161(21):2573-2578. [pmid: 11718588].
41 Jacobs DR, Pereira MA, Meyer KA, Kushi LH. Fiber from whole grains, but not refined grains, is inversely associated with all‐cause mortality in older women: the Iowa women's health study. J Am Coll Nutr. 2000;19(suppl 3):326S-330S. [pmid: 11386193].
42 Joshipura KJ, Hu FB, Manson JE, et al. The effect of fruit and vegetable intake on risk for coronary heart disease. Ann Intern Med. 2001;134(12):1106-1114. [pmid: 11412050].
43 Liu S, Manson JE, Stampfer MJ, et al. Whole grain consumption and risk of ischemic stroke in women: A prospective study. JAMA. 2000;284(12):1534-1540. [pmid: 11000647].
44 Stevens VJ, Glasgow RE, Toobert DJ, Karanja N, Smith KS. Randomized trial of a brief dietary intervention to decrease consumption of fat and increase consumption of friuts and vegetables. Am J Health Promot. 2002;16(3):129-134. [pmid: 11802257].
45 Wylie‐Rosett J. Fat substitutes and health: an advisory from the Nutrition Committee of the American Heart Association. Circulation. 2002;105:2800-2804. [pmid: 12057998].
46 American Cancer Society. Recommendations for nutrition and physical activity for cancer prevention. Available at: http://www.cancer.org. Accessed August 28, 2002.
47 Nawaz H, Katz DL. American College of Preventive Medicine Policy Statement: weight management counseling of overweight adults. Am J Prev Med. 2001;21(1):73-78. [pmid: 11418263].
48 American Academy of Family Physicians. Summary of policy recommendations for periodic health examinations, revision 5.1. Available at: http://www.aafp.org/exam.xml. Accessed August 28, 2002.
49 American Academy Of Pediatrics. Committee on Nutrition. Policy statement: Cholesterol in Childhood (RE9805). Pediatrics 1998;101(1):141‐147. Available at: http://www.aap.org/policy/re9805.html. Accessed August 28, 2002.
50 American College of Obstetricians and Gynecologists. Guidelines for Women's Health Care. 2nd ed. Washington, DC: ACOG; 2002:121‐34, 196‐200.
51 Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventive Health Care. Ottawa: Health Canada; 1994:586‐599. Available at: http://www.ctfphc.org./Accessed August 28, 2002.
52 Maillet JO, Young EA. Nutrition education for healthcare professionals: Position of the ADA. J Am Diet Assoc. 1998;98:343-346. [pmid: 9508021].
53 Sixth report of the Joint National Committee on Prevention, Detection, Evaluation and Treatment of High Blood Pressure. Bethesda, MD: National Heart Lung and Blood Institute; 1997. Available at: http://www.nhlbi.nih.gov/guidelines/hypertension/jncintro.htm. Accessed August 28, 2002.
54 Third report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). Bethesda, MD: National Heart Lung and Blood Institute; 2001. Available at: http://www.nhlbi.nih.gov/guidelines/cholesterol/index.htm. Accessed August 28, 2002.