# Discussion

Medium‐ to high‐intensity behavioral interventions appear to produce consistent, sustained, and clinically important changes in dietary intake of total fat, saturated fat, fruit and vegetables, and fiber. However, these trials were generally either conducted with patients with known risk factors for diet‐related chronic disease, or performed in special clinics with highly selected patients and specially trained providers. The most effective interventions generally combined education, behaviorally‐oriented counseling, and patient reinforcement and followup. More intensive interventions, and those of longer duration, are associated with larger magnitude of benefit and more sustained changes in diet.

Available studies do not, however, allow firm conclusions about the essential or most effective elements of these multi‐component interventions, their relative effect on specific dietary constituents (e.g., fat, fruit and vegetables, or fiber), or the relative efficacy of targeting single or multiple dietary risks or addressing diet in the context of broader lifestyle interventions. Although evidence is stronger for counseling patients who are at increased risk for chronic disease, such as those with hyperlipidemia, than for the general population of patients, it is not possible to disentangle the effects of patient risk status from the effects of intervention intensity. Adherence to these intensive interventions and the dietary changes they require may be dependent on patients' heightened perceived risk and motivation for change.

Existing trials of routine dietary interventions in unselected primary care populations have generally produced only small‐to‐medium changes in self‐reported diet. Although direct comparisons cannot be made, results from medium‐intensity, routine face‐to‐face counseling from nutritionists, dietitians, or specially trained primary care practitioners (physicians, nurses, or nurse practitioners) appear similar to those achieved through less intensive, minimal‐contact interventions to supplement brief primary care provider advice/counseling. The consistently positive effects of such interventions on diet in unselected patient populations establish these interventions as highly promising as part of routine preventive care for patients at average risk for chronic disease.

The USPSTF concluded, however, that existing studies do not provide sufficient evidence to recommend these interventions for widespread use due to a number of limitations such as modest overall patient recruitment/participation rates, reliance on self‐reported outcome measures, relatively short followup periods, uncertainty about the health effects of small and medium changes in diet, and the lack of evidence about possible adverse effects of counseling. Two studies suggest high‐intensity interventions can be effective in selected patients at average risk, but the applicability of these findings and the feasibility of these interventions in primary care settings are uncertain.^14^,^35^