# Clinical Considerations

- Several brief dietary assessment questionnaires have been validated for use in the primary care setting.^7,^ ^8^ These instruments can identify dietary counseling needs, guide interventions, and monitor changes in patients' dietary patterns. However, these instruments are susceptible to the bias of the respondent. Therefore, when used to evaluate the efficacy of counseling, efforts to verify self‐reported information are recommended since patients receiving dietary interventions may be more likely to report positive changes in dietary behavior than control patients.^9^‐^12^
- Effective interventions combine nutrition education with behaviorally‐oriented counseling to help patients acquire the skills, motivation, and support needed to alter their daily eating patterns and food preparation practices. Examples of behaviorally‐oriented counseling interventions include teaching self monitoring, training to overcome common barriers to selecting a healthy diet, helping patients to set their own goals, providing guidance in shopping and food preparation, role playing, and arranging for intra treatment social support. In general, these interventions can be described with reference to the 5‐A behavioral counseling framework^13^:
  1. Assess dietary practices and related risk factors.
  2. Advise to change dietary practices.
  3. Agree on individual diet change goals.
  4. Assist to change dietary practices or address motivational barriers.
  5. Arrange regular followup and support or refer to more intensive behavioral nutritional counseling (e.g., medical nutrition therapy) if needed.
- Two approaches appear promising for the general population of adult patients in primary care settings:
  1. Medium‐intensity face‐to‐face dietary counseling (two to three group or individual sessions) delivered by a dietitian or nutritionist or by a specially trained primary care physician or nurse practitioner.
  2. Lower‐intensity interventions that involve 5 minutes or less of primary care provider counseling supplemented by patient self‐help materials, telephone counseling, or other interactive health communications.
    However, more research is needed to assess the long‐term efficacy of these treatments and the balance of benefits and harms.
- The largest effect of dietary counseling in asymptomatic adults has been observed with more intensive interventions (multiple sessions lasting 30 minutes or longer) among patients with hyperlipidemia or hypertension, and among others at increased risk for diet‐related chronic disease. Effective interventions include individual or group counseling delivered by nutritionists, dietitians, or specially trained primary care practitioners or health educators in the primary care setting or in other clinical settings by referral. Most studies of these interventions have enrolled selected patients, many of whom had known diet‐related risk factors such as hyperlipidemia or hypertension. Similar approaches may be effective with unselected adult patients, but adherence to dietary advice may be lower, and health benefits smaller, than in patients who have been told they are at higher risk for diet‐related chronic disease.^14^
- Office‐level systems supports (prompts, reminders, and counseling algorithms) have been found to significantly improve the delivery of appropriate dietary counseling by primary care clinicians.^15^‐^17^
- Possible harms of dietary counseling have not been well defined or measured. Some have raised concerns that if patients focus only on reducing total fat intake without attention to reducing caloric intake, an increase in carbohydrate intake (e.g., reduced‐fat or low‐fat food products) may lead to weight gain, elevated triglyceride levels, or insulin resistance. Nationally, obesity rates have increased despite declining fat consumption, but studies did not consistently examine effects of counseling on outcomes such as caloric intake and weight.
- Little is known about effective dietary counseling for children or adolescents in the primary care setting. Most studies of nutritional interventions for children and adolescents have focused on non‐clinical settings (such as schools) or have used physiologic outcomes such as cholesterol or weight rather than more comprehensive measures of a healthy diet.^5,^ ^6^