# References

1 Guise JM, Palda V, Westhoff C, Chan B, Helfand M, Lieu TA. The Effectiveness of Primary Care Based Interventions to Promote Breastfeeding: A Systematic Evidence Review and Meta‐analysis for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality. May 2003. Available on the AHRQ Web site at: www.preventiveservices.ahrq.gov.
2 American Academy of Pediatrics and American College of Obstetricians and Gynecologists. Guidelines for Perinatal Care, 5th ed. October 2002: 220‐29.
3 Duncan B, Ey J, Holberg CJ, et al. Exclusive breast‐feeding for at least 4 months protects against otitis media. Pediatrics. 1993;91:867-72. [pmid: 8474804].
4 Kramer MS, Chalmers B, Hodnett ED, et al. Promotion of Breastfeeding Intervention Trial (PROBIT): a randomized trial in the Republic of Belarus. JAMA. 2001;285:413-20. [pmid: 11242425].
5 Howie PW, Forsyth JS, Ogston SA, et al. Protective effect of breastfeeding against infection. Br Med J. 1990;300:11-6. [pmid: 2105113]. [pmcid: 1661904].
6 Oddy WH, Holt PG, Sly PD, et al. Association between breastfeeding and asthma in 6‐year‐old children: findings of a prospective birth cohort study. Br Med J. 1999;319:815-9. [pmid: 10496824]. [pmcid: 314207].
7 Beaudry M, Dufour R, Marcoux S. Relation between infant feeding and infections during the first six months of life. J Pediatr. 1995;126:191-219. [pmid: 7844664].
8 American Academy of Pediatrics, Committee on Drugs. Policy statement: the transfer of drugs and other chemicals into human milk Pediatrics 2001 108 776 89 11533352
9 U.S. Department of Health and Human Services. Healthy People 2010, Conference ed. Vols I and II. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Office of the Assistant Secretary for Health, January 2000. Available from: http://www.health.gov/healthypeople/document/HTML/Volume2/16MICH.htm#_Toc494699668.
10 Duffy EP, Percival P, Kershaw E. Positive effects of an antenatal group teaching session on postnatal nipple pain, nipple trauma and breast feeding rates. Midwifery. 1997;13(4):189-96. [pmid: 9511686].
11 Pugh LC, Milligan RA. Nursing intervention to increase the duration of breastfeeding. Appl Nurs Res. 1998;11(4):190-4. [pmid: 9852662].
12 Brent NB, Redd B, Dworetz A, D'Amico F, Greenberg JJ. Breastfeeding in a low‐income population. Program to increase incidence and duration. Arch Pediatr Adolesc Med. 1995;149(7):798-803. [pmid: 7795772].
13 Sciacca JP, Dube DA, Phipps BL, Ratliff MI. A breast feeding education and promotion program: effects on knowledge, attitudes, and support for breast feeding. J Community Health. 1995;20(6):473-90. [pmid: 8568022].
14 Caulfield LE, Gross SM, Bentley ME, et al. WIC‐based interventions to promote breastfeeding among African‐American Women in Baltimore: effects on breastfeeding initiation and continuation. J Hum Lact. 1998;14(1):15-22. [pmid: 9543954].
15 Schafer E, Vogel M, Viegas S, Hausafus C. Volunteer peer counselors increase breastfeeding duration among rural low income women. Birth. 1998;25:101-6. [pmid: 9668744].
16 McInnes R, Love J, Stone D. Evaluation of a community‐based intervention to increase breastfeeding prevalence. J Hum Lact. 2000;22:138-45.
17 Curro V, Lanni R, Scipione F, Grimaldi V, Mastroiacovo P. Randomised controlled trial assessing the effectiveness of a booklet on the duration of breast feeding. Arch Dis Child 1997;76(6):500‐3; Discussion, 503‐4.
18 Redman S, Watkins J, Evans L, Lloyd D. Evaluation of an Australian intervention to encourage breastfeeding in primiparous women. Health Promot Internat. 1995;10(2):101-13.
19 Rossiter JC. The effect of a culture‐specific education program to promote breastfeeding among Vietnamese women in Sydney. Int J Nurs Stud. 1994;31(4):369-79. [pmid: 7928125].
20 Grossman LK, Harter C, Sachs L, Kay A. The effect of postpartum lactation counseling on the duration of breastfeeding in low‐income women. Am J Diseases of Children. 1990;144(4):471-4. [pmid: 2321612].
21 Donnelly A, Snowden H, Renfrew M, Woolridge M. Commercial hospital discharge packs for breastfeeding women. Cochrane Database of Systematic Reviews 2001;3.
22 Wang EEL. Breast feeding. In: Canadian Task Force on the Periodic Health Examination, ed. Canadian Guide to Clinical Preventive Health Care. Ottawa: Health Canada; 1994:232‐242. Available from: URL: www.hc‐sc.gc.ca/hppb/healthcare/pubs/clinical_preventive/sec2e.htm (http://www.hc-sc.gc.ca/hppb/healthcare/pubs/clinical_preventive/sec2e.htm).
23 American Academy of Family Physicians. Breastfeeding (Position Paper). Available from: URL: www.aafp.org/x6633.xml.
24 WHO/UNICEF. Protecting, promoting and supporting breastfeeding: the special role of maternity services. A joint WHO/UNICEF statement. Int J Gynaecol Obstet 1990; 31(suppl 1): 171‐83. Additional information at www.who.int/nut/inf.htm.
25 American Academy of Pediatrics. Breastfeeding and the use of human milk. American Academy of Pediatrics. Work Group on Breastfeeding. Pediatrics 1997;100(6):1035‐9. Accessible at www.aap.org/policy/re9729.html.
26 American College of Obstetricians and Gynecologists. Breastfeeding: maternal and infant aspects. ACOG Educational Bulletin 258. Washington, DC: ACOG, 2000.
27 Breaking the barriers to breastfeeding—Position of ADA. J Am Diet Assoc. 2001;101:1213. [pmid: 11678497].
28 International Lactation Consultation Association. Evidence‐based guidelines for breastfeeding management during the first fourteen days. International Lactation Consultation Association. Apr 1999.