# Recommendations of Others

The Canadian Task Force on Preventive Health Care (CTFPHC) concludes that there is good evidence to counsel women to breastfeed and to implement peripartum interventions that promote breastfeeding.^22^ The CTFPHC is in the process of updating its recommendation. The American Academy of Family Physicians recommends that physicians counsel pregnant women about breastfeeding and include behavioral supports, such as contact with lactation consultants, rooming‐in, and early initiation of breastfeeding.^23^ The World Health Organization, the United Nations Children's Fund, and the American Academy of Pediatrics (AAP) each recommend breastfeeding and include recommendations that clinicians promote breastfeeding, but none of these organizations include specific recommendations on the nature or extent of any counseling that should be undertaken by clinicians.^24^ ^,^ ^25^ The AAP also recommends that physicians work to promote support for breastfeeding at the department, hospital, and community level. Other organizations that support counseling to promote breastfeeding include the American College of Obstetricians and Gynecologists, the American Dietetic Association, and the International Lactation Consultants Association.^26^‐^28^