# Discussion

In order to promote wider use of effective breastfeeding programs, research is needed to examine barriers to their use, the costs and cost‐effectiveness of these programs and their individual components, and their effectiveness in more diverse populations and clinical settings.

The role of the primary obstetric, pediatric, or family medicine provider in promoting breastfeeding during clinical preventive visits has not received the attention it deserves. Because such visits are well‐established elements of routine prenatal and postnatal care, they have rich but untested potential to yield effective and cost‐effective approaches to breastfeeding promotion.