# Scientific Evidence

## Benefits of Breastfeeding

Breast milk is the optimal infant food. It has nutritional properties superior to formula and transmits protective immunoglobulins to the newborn. Observational studies in North America and Europe have found that breast‐fed infants have reduced rates of otitis media (odds ratios [OR] 0.39‐0.61)^3^ and respiratory infection (adjusted incidence density ratio 0.78)^4^ compared with non‐breast‐fed infants. A recent large randomized trial of breastfeeding promotion in Belarus found that breastfeeding reduces the incidence of gastroenteritis (adjusted OR, 0.60) and atopic eczema (adjusted OR, 0.54),^5^ consistent with the findings of earlier observational studies in other countries.^6^ ^,^ ^7^ For the mother, breastfeeding causes more rapid return of uterine tone and has been associated with lower risk for ovarian and breast cancer. Contraindications to breastfeeding are uncommon and include maternal HIV infection and the use of selected medications.^2^

National data from 1998 showed that 64 percent of all mothers breast‐fed postpartum, but only 29 percent of all mothers and only 19 percent of black mothers were breastfeeding by 6 months.^8^ Thus, the U.S. population falls short of the goals set by Healthy People 2010: for 75 percent of mothers to be breastfeeding immediately postpartum, 50 percent at 6 months, and 25 percent at 1 year.^9^

## Effectiveness of Structured Breastfeeding Education and Behavioral Counseling Programs

Several randomized controlled trials have found that structured breastfeeding education and behavioral counseling programs improve rates of breastfeeding initiation, breastfeeding duration, or both.^10^‐^13^ The most effective interventions used brief, relatively directive health education combined with behaviorally‐oriented skills training and problem‐solving counseling. They all used face‐to‐face sessions conducted outside the routine clinical visit. Several included efforts to bolster social support for breastfeeding initiation and maintenance, both in the health care setting (provider support, supportive hospital policies) and home setting (bolstering partner and/or family support for breastfeeding).

In most programs studied, nurses with advanced training as lactation consultants or midwives administered the interventions. Programs varied widely in other aspects of their format, including whether the sessions were for groups or individuals, the duration of sessions, and the number of sessions. Sessions generally ranged from 30 to 90 minutes, with participants attending from 1 to 8 sessions. Programs began during the prenatal period, and the majority included additional interventions (i.e., support, home visits, or written materials).^14^‐^17^ Baseline levels of breastfeeding varied widely among study populations: 31 percent to 83 percent of controls initiated breastfeeding and 14 percent to 82 percent of controls breast‐fed for 1 to 3 months.

A meta‐regression analysis of the available randomized controlled trials of breastfeeding interventions was conducted for the USPSTF. The purpose of this analysis was to assess the independent effects of breastfeeding education, ongoing support, and written materials.^1^ Educational programs increased the proportions of mothers initiating breastfeeding (risk difference 23%; 95% confidence interval [CI], 12‐34) and continuing to breastfeed for 1 to 3 months (risk difference 39%; 95% CI, 27‐50). These differences imply that enrolling 10 women in such programs will result in 2 additional women initiating breastfeeding and 4 additional women breastfeeding for 1 to 3 months. In pooled analysis, education did not significantly increase breastfeeding duration at 4 to 6 months (risk difference 4%; 95% CI, ‐6‐16).

## Effectiveness of Support From Providers and Peers

Eight randomized trials examined the effects of breastfeeding support used alone or in combination with breastfeeding education and counseling. These trials used lactation consultants, nurses, or peer counselors to provide pre‐arranged appointments and/or unscheduled, problem‐oriented visits or telephone calls. In the meta‐analysis conducted for the USPSTF,^1^ the independent effect of support alone on breastfeeding was modest: 6 percent (95% CI, ‐2‐15) for the initiation of breastfeeding; 11 percent (95% CI, 3‐19) for the continuation of breastfeeding for 1 to 3 months; and 8 percent (95% CI, 2‐16) for the continuation of breastfeeding for 4 to 6 months. Four studies examined the impact of education and support on the initiation and continuation of breastfeeding for up to 6 months. In pooled analysis, the combined effects of education and support significantly increased breastfeeding initiation (21%; 95% CI, 7‐35), its duration for 1 to 3 months (36%; 95% CI, 22‐49), and its duration for 4 to 6 months (13%; 95% CI, 1‐25). However, the effects of combined education and support on breastfeeding initiation and its continuation were not higher than the estimated effect of education alone.

No studies have evaluated whether advice by the woman's primary obstetric provider or by the infant's primary pediatric provider in the course of in‐hospital care or routine preventive visits is effective on its own in increasing breastfeeding rates.^13^

## Effectiveness of Other Breastfeeding Education and Support Measures

Peer counselors are potentially a useful source of support and motivation for breastfeeding. However, studies of peer counseling initiated from the clinical practice setting were judged to be of either poor quality or of limited generalizability due to the use of financial incentives as part of the intervention.^15^,^16^

Written materials alone do not appear effective in increasing breastfeeding rates. The evidence on whether written materials enhance the effectiveness of structured behavioral counseling programs is mixed. Few studies of in‐hospital interventions, including rooming‐in and early maternal contact, have been conducted in industrialized countries.^18^‐^20^ Those that have been conducted used multiple interventions, making it difficult to ascertain the benefit of each individual practice.

Commercial discharge packs for new mothers typically include free samples of infant formula, bottles, and plastic nipples. One recent systematic review found that such packs are associated with reduced rates of exclusive breastfeeding at 1 month and any breastfeeding at 4 months.^21^