# Clinical Considerations

- Effective breastfeeding education and behavioral counseling programs use individual or group sessions led by specially trained nurses or lactation specialists, usually lasting 30 to 90 minutes. Sessions generally begin during the prenatal period and cover the benefits of breastfeeding for infant and mother, basic physiology, equipment, technical training in positioning and latch‐on techniques, and behavioral training in skills required to overcome common situational barriers to breastfeeding and to garner needed social support.
- Hospital practices that may help support breastfeeding include early maternal contact with the newborn, rooming‐in, and avoidance of formula supplementation for breastfeeding infants.
- Commercial discharge packs provided by hospitals that include samples of infant formula and/or bottles and nipples are associated with reducing the rates of exclusive breastfeeding.
- Mothers who wish to continue breastfeeding after returning to work, especially those working full‐time, may need to use an electric or mechanical pump to maintain a sufficient breast milk supply.
- Few contraindications to breastfeeding exist. In developed countries, infection with human immunodeficiency virus (HIV) in the mother is considered a contraindication to breastfeeding, as is the presence of current alcohol and drug use/dependence. Some medications (prescription and non‐prescription) are contraindicated or advised for use "with caution" and appropriate clinical monitoring among lactating women.^2^ Clinicians should consult appropriate references for information on specific medications, including herbal remedies.