# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Harris RP, Lohr KN. Screening for prostate cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:917-29. [pmid: 12458993].
3 Harris RP, Lohr KN, Beck R, Fink K, Godley P, Bunton A. Screening for Prostate Cancer. Systematic Evidence Review No. 16 (Prepared by the Research Triangle Institute—University of North Carolina Evidence‐based Practice Center under Contract No. 290‐97‐0011). Rockville, MD: Agency for Healthcare Research and Quality. December 2001. (Available on the AHRQ Web site at: http://www.ahrq.gov/clinic/serfiles.htm).
4 American Cancer Society. Cancer facts and figures, 2001‐2002. Available at: http://www.cancer.org. Accessed March 01, 2002.
5 Ries LAG, Eisner MP, Kosary CL, Hankey BF, Miller BA, Clegg L, Edwards BK (eds). SEER Cancer Statistics Review, 1973‐1998, National Cancer Institute. Bethesda, MD; 2001. Available at: http://seer.cancer.gov/csr/1973_1999/.
6 National Cancer Institute. Surveillance, Epidemiology, and End Results (SEER) Program Public‐Use Data (1973‐1998). Available at:http://seer.cancer.gov. Accessed March 01, 2002.
7 Catalona WJ, Richie JP, Ahmann FR, et al. Comparison of digital rectal examination and serum prostate specific antigen in the early detection of prostate cancer: results of a multicenter clinical trial of 6,630 men. J Urol. 1994;151:1283-90. [pmid: 7512659].
8 Gann P, Hennekens C, Stampfer M. A prospective evaluation of plasma prostate‐specific antigen for detection of prostatic cancer. JAMA. 1995;273:289-94. [pmid: 7529341].
9 Mettlin C, Murphy GP, Babaian RJ, et al. The results of a five‐year early prostate cancer detection intervention. Investigators of the American Cancer Society National Prostate Cancer Detection Project. Cancer. 1996;77:150-9. [pmid: 8630923].
10 Jacobsen SJ, Bergstralh EJ, Guess HA, et al. Predictive properties of serum‐prostate‐specific antigen testing in a community‐based setting. Arch Intern Med. 1996;156:2462-8. [pmid: 8944739].
11 Labrie F, Candas B, Dupont A, et al. Screening decreases prostate cancer death: first analysis of the 1988 Quebec prospective randomized controlled trial. Prostate. 1999;38:83-91. [pmid: 9973093].
12 Friedman G, Hiatt R, Quesenberry C, Selby J. Case‐control study of screening for prostatic cancer by digital rectal examinations. Lancet. 1991;337:1526-9. [pmid: 1675379].
13 Richert‐Boe KE, Humphrey LL, Glass AG, Weiss NS. Screening digital rectal examination and prostate cancer mortality: a case‐control study. J Med Screen. 1998;5:99-103. [pmid: 9718529].
14 Jacobsen SJ, Bergstralh EJ, Katusic SK, et al. Screening digital rectal examination and prostate cancer mortality: a population‐based case‐control study. Urology. 1998;52:173-9. [pmid: 9697778].
15 Holmberg L, et al. A randomized trial comparing radical prostatectomy with watchful waiting in early prostate cancer. N Engl J Med. 2002;347:781-9. [pmid: 12226148].
16 Litwin MS, Hays RD, Fink A, et al. Quality of life outcomes in men treated for localized prostate cancer. JAMA. 1995;273:129-35. [pmid: 7799493].
17 Steineck G, Helgesen F, Adolfsson J, et al. Quality of life after radical prostatectomy or watchful waiting. N Engl J Med. 2002;347:790-6. [pmid: 12226149].
18 Periodic Health Examinations: Summary of AAFP Policy and Recommendations & Age Charts. Available at: http://www.aafp.org/exam. Accessed March 01, 2002.
19 American Cancer Society guidelines for the early detection of cancer: update of early detection guidelines for prostate, colorectal, and endometrial cancers. Also: Update 2001—testing for early lung cancer detection. CA Cancer J Clin 2001 Jan‐Feb;51(1):38‐75. Accessed at http://www.cancer.org on 25 October, 2002.
20 American College of Physicians. Clinical guideline part III: screening for prostate cancer Ann Intern Med 1997 126 480 4 9072936
21 American Medical Association. Report 9 of the Council on Scientific Affairs (A‐00). Screening and Early Detection of Prostate Cancer. June 2001. Available at: http://www.ama‐assn.org/ama/pub/article/2036‐2928.html (http://www.ama-asssn.org/ama/pub/article/2036-2928.html). Accessed March 01, 2001.
22 Prostate‐specific antigen (PSA) best practice policy. American Urological Association (AUA). Oncology (Huntingt). 2000 Feb;14(2):267‐72. Accessed at http://www.auanet.org on October 25, 2002.
23 Canadian Task Force on the Periodic Health Examination. Ottawa (Canada): Health Canada; 1994. Available at: http://www.ctfphc.org/index.html. Accessed March 01, 2002.