# Recommendations of Others

Most major U.S. medical organizations recommend that clinicians:

- Discuss with patients the potential benefits and possible harms of PSA screening.
- Consider patient preferences.
- Individualize the decision to screen.

They generally agree that the most appropriate candidates for screening include men older than 50 and younger men at increased risk of prostate cancer, but that screening is unlikely to benefit men who have a life expectancy of less than 10 years. These organizations include

- The American Academy of Family Physicians.
- The American Cancer Society.
- The American College of Physicians‐American Society of Internal Medicine.
- The American Medical Association.
- The American Urologic Association.^18^‐^22^

None of these organizations endorses universal or mass screening for any group of men.

In 1994, the Canadian Task Force on Preventive Health Care recommended against the routine use of PSA or TRUS as part of the periodic health examination^23^; while recognizing the limitations of DRE, it concluded that the evidence was insufficient to recommend that physicians discontinue use of DRE in men aged 50 to 70. The Canadian Task Force is in the process of updating their recommendations.