# Scientific Evidence

## Epidemiology and Clinical Consequences

BV describes an imbalance in the normal vaginal bacterial flora characterized by a decrease in Lactobacilli and an increase in Gardnerella, Mycoplasma, and anaerobic bacteria. BV is a common cause of abnormal vaginal discharge and has been associated with adverse pregnancy outcomes. The true prevalence of BV in the community is not known. Studies in academic medical centers and public hospitals found that 9% to 23% of pregnant women had BV, with infection more common among African-American women than Caucasian women.

Observational studies have consistently shown an association between BV and adverse pregnancy outcomes, including preterm delivery (relative risks [RRs] ranging from 1.4 to 6.9), preterm premature rupture of membranes (RR=2.0 to 7.3), spontaneous abortion (RR=1.3 to 2.0), and preterm labor (RR=2.0 to 2.6). Preterm delivery is associated with significant respiratory, neurologic, and developmental abnormalities in the newborn that might result in death or long-term disability. A short course of antibiotic therapy can alter the microflora imbalance associated with BV, but cure rates are variable and recurrences are common. Because BV may be a marker for adverse pregnancy outcomes, rather than a causative factor, controlled trials have been conducted to determine whether treating BV will also improve pregnancy outcomes.

## Accuracy and Reliability of Screening Test

The screening test employed in most epidemiologic studies and treatment trials of BV has been the Gram stain of the vaginal discharge. In practice, a combination of other clinical findings is usually used (see Clinical Considerations). Comparisons of clinical criteria and Gram stain yield sensitivities from 62% to 97% and specificities from 66% to 95%, using the Gram stain as the standard. The use of more limited diagnostic criteria has not been evaluated in studies of adverse pregnancy outcomes.

## Effectiveness of Treatment of Bacterial Vaginosis

Seven randomized controlled trials have evaluated the effect of various antibiotic treatments versus placebo on pregnancy outcomes among women with BV: Three studies enrolled only high-risk women (primarily history of prior preterm delivery), two reported results separately for women with and without a prior history of preterm delivery, and two enrolled average-risk women. Among four studies reporting results for average-risk women, there were no differences between control groups and treatment groups in rates of preterm delivery, preterm premature rupture of membranes, or delivery of low birth weight infants.

Five studies reported conflicting results among women at increased risk because of a history of preterm delivery in previous pregnancies. Oral antibiotic treatment reduced the incidence of preterm delivery before 37 weeks in three studies, which enrolled women at particularly high risk (incidence of preterm delivery in placebo groups 35% to 57%). In contrast, in a large, multicenter, American trial completed in 1999, a different regimen of oral metronidazole provided no benefit for the subgroup of women who had a history of previous preterm delivery. A fifth small study reported no benefit of vaginal clindamycin among high-risk women.

## Potential Adverse Effects of Screening and Treatment

Because BV is common, screening and treatment could subject a substantial number of women to the inconvenience and minor side effects (primarily nausea) of taking metronidazole and other antibiotics during pregnancy. The regimens used to treat BV are generally considered safe in pregnancy, but several studies raise the possibility of harms in some women or their infants. In two studies, a subgroup of women who did not have BV but received treatment with metronidazole or clindamycin experienced trends toward higher incidence of preterm delivery before 34 weeks gestation (12% to 13% vs 4% to 5%). In addition, neonatal sepsis was significantly increased among women receiving vaginal clindamycin.