# Scientific Evidence

## Epidemiology and Clinical Consequences

Prostate cancer is the second leading cause of cancer‐related death among men in the United States (second to lung cancer).^2^ In 2002, an estimated 189,000 new cases of prostate cancer will be diagnosed in American men, and approximately 30,200 men will die from the disease.^4^ The risk of developing prostate cancer increases beginning at age 40. The probability of developing prostate cancer over the next 10 years is 0. 17 percent for men aged 40, 2. 01 percent for men aged 50, and 6. 46 percent for men aged 60.^5^

The burden of prostate cancer varies among different racial and ethnic groups. African American men have about a 60 percent higher incidence rate and a 2‐fold higher mortality rate from prostate cancer than white men.^2^ Compared with white men, mortality from prostate cancer is 35 percent lower in Non‐white Hispanics and 40 percent lower in Asian Americans and Pacific Islanders.^6^

Although prostate cancer is a major cause of cancer death, many more men are diagnosed with this cancer than die from it. Men in the United States have a 15 percent lifetime risk of being diagnosed with prostate cancer but only a 3 percent lifetime risk of dying from the disease.^5^ More than 75 percent of all cases of prostate cancer are diagnosed in men older than 65, and 90 percent of prostate cancer deaths occur among men in this age group.^2^ The prostate cancer mortality rate declined 19.4 percent between 1991 and 1998, but the causes of this decline are uncertain.^5^

Tumor grade appears to be a stronger predictor of prognosis than stage of disease. In studies of untreated prostate cancer, well‐differentiated tumors had low rates of metastasis or mortality over 10 years. Progression and mortality were high for poorly differentiated cancers.^3^

## Accuracy and Reliability of Screening Tests

DRE and PSA are the two principal tests currently used in the United States to screen for prostate cancer. Determining test characteristics of any screening test for prostate cancer is difficult because clinicians disagree on which cancers are "clinically important," and thus disagree on an appropriate target for early detection. The gold standard often used in screening studies—needle biopsy—may miss cancers that are present. Conversely, needle biopsy may serendipitously detect cancers unrelated to abnormal screening results. Especially in asymptomatic older men, screening with DRE and PSA may detect cancers that appear clinically significant based on size and tumor grade, but which would not have progressed to clinical symptoms during the patient's lifetime.

DRE is limited by the fact that only the posterior and lateral aspects of the gland can be palpated and the fact that different examiners often disagree about whether a DRE is abnormal. An overview of studies of screening suggests that DRE alone detects less than 60 percent of prevalent prostate cancers.^3^ Adding DRE to PSA does appear to increase the yield of screening; in a large study of volunteers, the combination of DRE and PSA detected 26 percent more cancers than PSA alone.^7^ However, combining DRE and PSA also increases the rate of false positive results.

Sensitivity and specificity of PSA screening depend on the value used to define an abnormal PSA result. If a cut‐point of 4.0 ng/ml is used, PSA screening has an estimated sensitivity of 63‐83 percent for "clinically significant" disease using pathological criteria.^3^ In a retrospective study of clinically diagnosed cancers prior to widespread screening, PSA levels were above 4 ng/ml in 91 percent of patients who were diagnosed with "aggressive" cancers over the 2 years following the test.^8^ Specificity of a cut‐point of 4.0 ng/ml has been estimated at around 90 percent on the first screening round but declines with increasing age and the presence of benign prostatic hypertrophy (BPH).^3^ ^,^ ^9^ One study reported specificity of 98 percent for men in their 50s but specificity of only 81 percent for men in their 70s.^10^ Even lower specificity rates have been found in men with documented BPH.^3^ Conditions such as prostatitis may also raise PSA levels.^3^

Variations of the PSA test have been developed, primarily to improve the specificity of the test (i.e., to reduce false positives). These include PSA density (the ratio of the PSA level to the volume of the prostate as measured by trans‐rectal ultrasound (TRUS), PSA velocity (the rate at which the PSA increases over time), age‐ and race‐adjusted reference ranges, and percentage of free PSA (the proportion of total PSA that is not bound to serum proteins).^3^ There is insufficient evidence that these variations will improve the accuracy of screening in practice, however.

The yield of screening varies with the age of the population, screening history, and screening protocol. In studies of generally unscreened populations of men aged 45 to 80, 7‐13 percent had a PSA [underlined: >]4 ng/ml; of these, 10‐30 percent had cancer on biopsy.^3^ Overall, initial screening detects cancer in 0.2‐2 percent of men in their 50s and 3‐7 percent of men in their 70s.^3^ Yield of screening declines substantially with subsequent annual screenings, especially among men who have low PSA values on initial screening.^2^

About 70 percent of cancers detected in the first round of screening are pathologically organ confined; this percentage increases with subsequent annual rounds of screening.^3^,^7^ Between 5 percent and 10 percent of cancers detected by screening are poorly differentiated^3^; the proportion of cancers that are well‐differentiated varies among studies, but most cancers detected by screening are moderately differentiated. The extent to which earlier detection of these cancers leads to improved outcomes is uncertain. The yield of screening in terms of cancers detected declines rapidly with repeated annual testing.^3^ ^,^ ^11^

## Effectiveness of Early Detection

The USPSTF found one randomized controlled trial (RCT) and three case‐control studies examining the effect of screening on prostate cancer mortality. The single RCT of PSA and DRE screening, which reported a benefit from screening, was hampered by a low rate of acceptance of screening in the intervention group (23 percent) and by flaws in the published analysis.^11^ No difference in the number of prostate cancer deaths was observed between the groups randomized to screening versus usual care using "intention to treat" analysis.^3^ Three case‐control studies of screening DRE produced mixed results.^12^ ^,13,^ ^14^ A number of RCTs of PSA screening for prostate cancer are underway in both the United States and Europe, but they are not expected to report results for several years.

Data are also limited to determine whether and how much treatment of screening‐detected cancers improves outcomes. Radical prostatectomy and radiation are the most commonly used treatments for localized prostate cancer, yet few well‐conducted randomized controlled trials have been completed to determine whether these treatments reduce mortality or are more effective than "watchful waiting" (deferring treatment until symptoms or disease progression is evident) for organ‐confined prostate cancer.

A recent large, good quality RCT^15^ reported that prostatectomy, compared with watchful waiting, significantly lowered the probabilities of dying of prostate cancer (4.6 percent vs 8.9 percent) and of developing distant metastases (13.4 percent vs 27.3 percent) after 8 years for men with clinically detected, organ‐confined cancer that was well‐ or moderately differentiated; reduction in total mortality was smaller and not significant (20 percent vs 28 percent). Although important, this study does not establish a benefit of screening due to several factors: screening‐detected cancers (only 5 percent of the cases in this study) may have a less aggressive course than clinically detected cancers, and the delay between treatment and benefit (5 years in this study) is likely to be even longer due to "lead time" from screening (i.e., PSA screening may detect cancers 4 or more years earlier than they would be detected clinically). Finally, this study cannot address how much better outcomes would have been if treatments were begun earlier as a result of screening.

A similar ongoing study in the United States, where most cases of prostate cancer are detected by screening, may provide information more relevant to the benefits of early detection through screening. In observational studies, outcomes are worst, and the potential impact of aggressive treatment are greatest, for poorly differentiated cancers.^3^

In the absence of better data about which treatments are effective for which tumors, the USPSTF could not determine whether the increased detection of prostate cancer from screening would reduce mortality and morbidity.

The USPSTF also examined a variety of ecologic data, including studies of secular trends in prostate cancer mortality, after the introduction of PSA screening and comparisons of prostate cancer mortality rates in communities with and without screening.^2^ Prostate cancer mortality rates in the United States have declined since 1991.^5^ However, the available ecologic studies have not provided sufficient evidence that the decline in prostate cancer in the United States or other countries are attributable to screening; differences in prostate cancer treatment, underlying risk factors, and how deaths are classified can all introduce bias into ecological comparisons.

## Potential Adverse Effects of Screening

Evidence about the harms of screening per se is scant. The screening process is likely associated with some increase in anxiety, but the number of men affected and the magnitude of the increased anxiety are largely unknown. Some screening procedures cause transient discomfort. Fewer than 10 percent of men have ongoing interference with daily activities after biopsy, and fewer than 1 percent suffer more serious complications, including infections.^3^

Screening may result in harm if it leads to treatments that have side effects without improving outcomes from prostate cancer, especially for cancers that have a lower chance of progressing. Erectile dysfunction, urinary incontinence, and bowel dysfunction are well‐recognized and relatively common adverse effects of treatment with surgery, radiation or androgen ablation, but men differ in their responses to these symptoms.^2^ ^,^ ^16^ In a recent trial, patients undergoing prostatectomy were more likely to have erectile dysfunction (80 percent vs 45 percent) and urinary leakage (49 percent vs 21 percent) than patients receiving watchful waiting, but both groupsreported similar outcomes on measures of quality of life and psychological and physical well‐being.^17^

## Cost and Cost‐effectiveness

Given uncertainties about the effectiveness of screening and the balance of benefits and harms, the cost‐effectiveness of screening for prostate cancer is impossible to determine. If one makes favorable assumptions about efficacy of screening, PSA screening may be cost‐effective for men aged 50 to 69.^2^ If efficacy of early treatment is lower, harms could exceed benefits and PSA screening would not be cost‐effective. Current models show that men older than 70 to 75 are unlikely to benefit substantially from screening because of their shorter life‐expectancy and higher false‐positive rates.^2^ Cost‐effectiveness of different screening intervals or variations of PSA measurement is unknown.