# Clinical Considerations

- Prostate specific antigen (PSA) testing and digital rectal examination (DRE) can effectively detect prostate cancer in its early pathologic stages. Recent evidence suggests that radical prostatectomy can reduce prostate cancer mortality in men whose cancer is detected clinically. The balance of potential benefits (the reduction of morbidity and mortality from prostate cancer) and harms (false‐positive results, unnecessary biopsies, and possible complications) of early treatment of the types of cancers found by screening, however, remains uncertain. Therefore, the benefits of screening for early prostate cancer remain unknown. Ongoing screening trials, and trials of treatment versus "watchful waiting" for cancers detected by screening, may help clarify the benefits of early detection of prostate cancer.
- Despite the absence of firm evidence of effectiveness, some clinicians may opt to perform prostate cancer screening for other reasons. Given the uncertainties and controversy surrounding prostate cancer screening, clinicians should not order the PSA test without first discussing with the patient the potential but uncertain benefits and the possible harms of prostate cancer screening. Men should be informed of the gaps in the evidence, and they should be assisted in considering their personal preferences and risk profile before deciding whether to be tested.
- If early detection improves health outcomes, the population most likely to benefit from screening will be men aged 50 to 70 who are at average risk, and men older than 45 who are at increased risk (African American men and men with a family history of a first‐degree relative with prostate cancer).^2^ Benefits may be smaller in Asian Americans, Hispanics, and other racial and ethnic groups that have a lower risk of prostate cancer. Older men and men with other significant medical problems who have a life expectancy of fewer than 10 years are unlikely to benefit from screening.^2^
- PSA testing is more sensitive than DRE for the detection of prostate cancer. PSA screening with the conventional cut‐point of 4.0 ng/ml detects a large majority of prostate cancers; however, a significant percentage of early prostate cancers (10‐20 percent) will be missed by PSA testing alone.^3^ Using a lower threshold to define an abnormal PSA detects more cancers at the cost of more false positives and more biopsies.
- The yield of screening in terms of cancer detected declines rapidly with repeated annual testing.^2^ If screening were to reduce mortality, biennial PSA screening could yield as much benefit as annual screening.