# References

1 Sheridan S, Pignone M, Donahue K. Screening for high blood pressure: A Review of the Evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2003;25:151-8. [pmid: 12880884].
2 U.S. Preventive Services Task Force. Screening for high blood pressure. In: Guide to Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996. p. 39‐51.
3 The sixth report of the Joint National Committee on prevention, detection evaluation, and treatment of high blood pressure. Arch Intern Med 1997;157:2413-46.
4 Padwal R, Straus SE, McAlister FA. Evidence based management of hypertension. Cardiovascular risk factors and their effects on the decision to treat hypertension: evidence based review. BMJ. 2001;322(7292):977-80. [pmid: 11312234].
5 Klein R, Klein BE, Moss SE. The relation of systemic hypertension to changes in the retinal vasculature: the Beaver Dam Eye Study. Trans Am Ophthalmol Soc 1997;95:329‐48; discussion 348‐50.
6 Lederle FA, Johnson GR, Wilson SE, et al. Prevalence and associations of abdominal aortic aneurysm detected through screening. Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Group. Ann Intern Med. 1997;126:441-9. [pmid: 9072929].
7 Hodgson TA, Cai L. Medical care expenditures for hypertension, its complications, and its comorbidities. Med Care. 2001;39:599-615. [pmid: 11404643].
8 Collins R, Peto R, MacMahon S, et al. Blood pressure, stroke, and coronary heart disease. Part 2, Short‐term reductions in blood pressure: overview of randomised drug trials in their epidemiological context. Lancet. 1990;335:827-38. [pmid: 1969567].
9 Adrogue HE, Sinaiko AR. Prevalence of hypertension in junior high school‐aged children: effect of new recommendations in the 1996 Updated Task Force Report. Am J Hypertens. 2001;14(5 Pt 1):412-4. [pmid: 11775140].
10 Bradley CB, Harrell JS, McMurray RG, et al. Prevalence of high cholesterol, high blood pressure, and smoking among elementary schoolchildren in North Carolina. N C Med J. 1997;58:362-7. [pmid: 9313361].
11 Feld LG, Springate JE. Hypertension in children. Curr Probl Pediatr. 1988;18:317-73. [pmid: 3048906].
12 Reeves RA. Does this patient have hypertension? How to measure blood pressure. JAMA. 1995;273:1211-8. [pmid: 7707630].
13 McAlister FA, Straus SE. Evidence based treatment of hypertension. Measurement of blood pressure: an evidence based review. BMJ. 2001;322:908-11. [pmid: 11302909].
14 Myers MG, Haynes RB, Rabkin SW. Canadian hypertension society guidelines for ambulatory blood pressure monitoring. Am J Hypertens. 1999;12(11 Pt 1):1149-57. [pmid: 10619579].
15 Verdecchia P, Porcellati C, Schillaci G, et al. Ambulatory blood pressure. An independent predictor of prognosis in essential hypertension. Hypertension. 1994;24:793-801. [pmid: 7995639].
16 Khattar RS, Swales JD, Banfield A, Dore C, Senior R, Lahiri A. Prediction of coronary and cerebrovascular morbidity and mortality by direct continuous ambulatory blood pressure monitoring in essential hypertension. Circulation. 1999;100:1071-6. [pmid: 10477532].
17 Staessen JA, Thijs L, Fagard R, et al. Predicting cardiovascular risk using conventional vs ambulatory blood pressure in older patients with systolic hypertension. Systolic Hypertension in Europe Trial Investigators. JAMA. 1999;282:539-46. [pmid: 10450715].
18 Appel LJ, Robinson KA, Guallar EG, et al. Utility of Blood Pressure Monitoring Outside of the Clinic Setting. Evidence Report/Technology Assessment Number 63. AHRQ Publication No. 03‐E004, November 2002. Agency for Healthcare Research and Quality, Rockville, MD. http://www.ahrq.gov/clinic/bpmoninv.htm.
19 The ALLHAT officers and coordinators for the ALLHAT Collaborative Research Group. Major cardiovascular events in hypertensive patients randomized to doxazosin vs chlorthalidone: the Antihypertensive and Lipid‐Lowering Treatment to Prevent Heart Attack Trial (ALLHAT) JAMA 2000 283 15 1967 75 10789664
20 The ALLHAT officers and coordinators for the ALLHAT Collaborative Research Group. Major outcomes in high‐risk hypertensive patients randomized to angiotensin‐converting enzyme inhibitor or calcium channel blocker vs diuretic: The Antihypertensive and Lipid‐Lowering Treatment to Prevent Heart Attack Trial (ALLHAT) JAMA 2002 288 2981 97 12479763
21 Gueyffier F, Froment A, Gouton M. New meta‐analysis of treatment trials of hypertension: improving the estimate of therapeutic benefit. J Hum Hypertens. 1996;10(1):1-8. [pmid: 8642184].
22 Staessen JA, Gasowski J, Wang JG, et al. Risks of untreated and treated isolated systolic hypertension in the elderly: meta‐analysis of outcome trials. Lancet. 2000;355:865-72. [pmid: 10752701].
23 UK Prospective Diabetes Study Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38 BMJ 1998 317 703 13 28659 9732337
24 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood‐pressure lowering and low‐dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. 1998;351(9118):1755-62. [pmid: 9635947].
25 Leiter LA, Abbott D, Campbell NR, Mendelson R, Ogilvie RI, Chockalingam A. Lifestyle modifications to prevent and control hypertension. 2. Recommendations on obesity and weight loss. Canadian Hypertension Society, Canadian Coalition for High Blood Pressure Prevention and Control, Laboratory Centre for Disease Control at Health Canada, Heart and Stroke Foundation of Canada. CMAJ. 1999;160(9 Suppl):S7-12. [pmcid: 305325]. [pmid: 10497606].
26 Cleroux J, Feldman RD, Petrella RJ. Lifestyle modifications to prevent and control hypertension. 4. Recommendations on physical exercise training. Canadian Hypertension Society, Canadian Coalition for High Blood Pressure Prevention and Control, Laboratory Centre for Disease Control at Health Canada, Heart and Stroke Foundation of Canada. CMAJ. 1999;160(9 Suppl):S21-8. [pmcid: 305325]. [pmid: 10497606].
27 Cutler JA, Follmann D, Allender PS. Randomized trials of sodium reduction: an overview. Am J Clin Nutr. 1997;65(2 Suppl):643S-51S. [pmid: 9394689].
28 Midgley JP, Matthew AG, Greenwood CM, Logan AG. Effect of reduced dietary sodium on blood pressure: a meta‐analysis of randomized controlled trials. JAMA. 1996;275(20):1590-7. [pmid: 8622251].
29 Whelton PK, He J, Cutler JA, et al. Effects of oral potassium on blood pressure. Meta‐analysis of randomized controlled clinical trials. JAMA. 1997;277(20):1624-32. [pmid: 9168293].
30 Xin X, He J, Frontini MG, Ogden LG, Motsamai OI, Whelton PK. Effects of alcohol reduction on blood pressure: a meta‐analysis of randomized controlled trials. Hypertension. 2001;38(5):1112-7. [pmid: 11711507].
31 Ameling EH, de Korte DF, Man in 't Veld A. Impact of diagnosis and treatment of hypertension on quality of life: a double‐blind, randomized, placebo‐controlled, cross‐over study of betaxolol. J Cardiovasc Pharmacol. 1991;18(5):752-60. [pmid: 1723773].
32 Mann AH. The psychological effect of a screening programme and clinical trial for hypertension upon the participants. Psychol Med. 1977;7(3):431-8. [pmid: 905459].
33 Ambrosio GB, Dissegna L, Zamboni S, Santonastaso P, Canton G, Dal Palu C. Psychological effects of hypertension labeling during a community survey. A two‐year follow‐up. J Hypertens Suppl. 1984;2(3):S171-3. [pmid: 6599664].
34 Rudd P, Price MG, Graham LE, et al. Consequences of worksite hypertension screening. Differential changes in psychosocial function. Am J Med. 1986;80(5):853-60. [pmid: 3706373].
35 Rudd P, Price MG, Graham LE, et al. Consequences of worksite hypertension screening. Changes in absenteeism. Hypertension. 1987;10(4):425-36. [pmid: 3653971].
36 Rastam L, Ryden L. Work absenteeism and well‐being in patients treated for hypertension. Eur Heart J. 1987;8(9):1024-31. [pmid: 3665953].
37 Alderman MH, Davis TK. Hypertension control at the work site. J Occup Med. 1976;18(12):793-6. [pmid: 825626].
38 Pearson TA, Blair SN, Daniels SR, et al. AHA Guidelines for Primary Prevention of Cardiovascular Disease and Stroke: 2002 Update. Circulation. 2002;106:388-91. [pmid: 12119259].
39 American Academy of Family Physicians (AAFP). Age Charts for Periodic Health Examinations. Revision 5.1 ed. Vol. 2002; 2001.
40 American College of Obstetricians and Gynecologists. Guidelines for Women's Health Care. 2nd ed. Washington, DC: ACOG; 2002. p. 121‐34.
41 Recommendations for preventive pediatric health care. Committee on Practice and Ambulatory Medicine Pediatrics 1995 96(2 Pt 1) 373 4 434508 7630705
42 Report of the Second Task Force on Blood Pressure Control in Children–1987. Task Force on Blood Pressure Control in Children. National Heart, Lung, and Blood Institute, Bethesda, Maryland Pediatrics 1987 79 1 1 25 3797155
43 American Heart Association (AHA). High Blood Pressure in Children. Vol. 2002; 2002.
44 Bright Futures: guidelines for health supervision of infants, children, and adolescents. Arlington: National Center for Education in Maternal and Child Health; 2002.
45 American Medical Association. Guidelines for Adolescent Preventive Services (GAPS). Vol. 2002; 1997.
46 American Academy of Pediatrics Committee on Fetus and Newborn: Routine evaluation of blood pressure, hematocrit, and glucose in newborns.Pediatrics 1993 92 3 474 6 8361812