# Recommendations of Others

Recommendations of the Joint National Committee (JNC) 6 call for routine blood pressure measurement at least once every 2 years for adults with a DBP below 85 mm Hg and a SBP below 130 mm Hg.3 (http://www.ahrq.gov/clinic/3rduspstf/highbloodsc/#3) JNC‐7 guidelines that update the JNC‐6 guidelines for the treatment of high blood pressure can be accessed at www.nhlbi.nih.gov/guidelines/hypertension/jncintro.htm. Similar recommendations have been issued by the American Heart Association (AHA) for adults beginning at age 20.^38^ The Canadian Task Force on Preventive Health Care is currently updating its recommendations on screening for elevated blood pressure. The American Academy of Family Physicians strongly recommends periodic measurement of blood pressure in patients older than 21.^39^ The American College of Obstetricians and Gynecologists recommends measuring blood pressure annually or as appropriate for women 13 and older.^40^ The American Academy of Pediatrics,^41^ the National Heart, Lung, and Blood Institute,^42^ the AHA,^43^ Bright Futures: Guidelines for Health Supervision of Infants, Children and Adolescents,^44^ and the American Medical Association^45^ recommend regular blood pressure measurements starting at the age of 3 years. The AAP further recommends against universal neonatal blood pressure screenings.^46^